# Appendix K. Extraction Form for Nonrandomized Controlled Clinical Trials

## Data extraction for non-RCTs but controlled intervention studies, page 1

[image]

## Data extraction for non-RCTs but controlled intervention studies, page 2

[image]

## Data extraction for non-RCTs but controlled intervention studies, page 3

[image]

## Data extraction for non-RCTs but controlled intervention studies, page 4

[image]

## Data extraction for non-RCTs but controlled intervention studies, page 5

[image]

## Data extraction for non-RCTs but controlled intervention studies, page 6

[image]