# Appendix J. Extraction Form for Randomized Clinical Trials

## Data extraction for RCTs, page 1

[image]

## Data extraction for RCTs, page 2

[image]

## Data extraction for RCTs, page 3

[image]

## Data extraction for RCTs, page 4

[image]

## Data extraction for RCTs, page 5

[image]

## Data extraction for RCTs, page 6

[image]

## Data extraction for RCTs, page 7

[image]

## Data extraction for RCTs, page 8

[image]

## Conversion of RCT intervention and outcome numbers to CODES

[image]