# Appendix A. Search Strategy: MEDLINE and HealthSTAR for Intervention Studies

Set Search

- 001 ventilator weaning/
- 002 trial$ of spontaneous breathing.ti,ab.
- 003 exp respiration, artificial/
- 004 exp intubation, intratracheal/
- 005 patient triggered ventilation.ti,ab.
- 006 (intermittent manditory ventilation or simv or imv).ti,ab.
- 007 positive pressure ventilation.ti,ab.
- 008 pressure support ventilation.ti,ab.
- 009 nippv.ti,ab.
- 010 mechanical ventilation.ti,ab.
- 011 (continuous positive airway pressure or cpap).ti,ab.
- 012 bipap.ti,ab.
- 013 wean$.ti,ab.
- 014 extubat$.ti,ab.
- 015 duration.ti,ab.
- 016 discontinu$.ti,ab.
- 017 or/3-12
- 018 or/13-16
- 019 17 and 18
- 020 1 or 2 or 19
- 021 randomized controlled trial.pt.
- 022 controlled clinical trial.pt.
- 023 randomized controlled trials.sh.
- 024 random allocation.sh.
- 025 double-blind method.sh.
- 026 single-blind method.sh.
- 027 or/21-26
- 028 (animal not human).sh.
- 029 27 not 28
- 030 clinical trial.pt.
- 031 exp clinical trials/
- 032 (clin$ adj25 trial:).ti,ab.
- 033 ((single$ or doubl$ or trebl$ or tripl$) adj25 (blind$))
- 034 placebos.sh.
- 035 placebo$.ti,ab.
- 036 random$.ti,ab.
- 037 research design.sh.
- 038 or/30-37
- 039 38 not 28
- 040 39 not 29
- 041 comparative study.sh.
- 042 exp evaluation studies/
- 043 follow-up studies.sh.
- 044 prospective studies.sh.
- 045 (control$ or prospectiv$ or vounteer$).ti,ab.
- 046 or/41-45
- 047 46 not 28
- 048 47 not (29 or 40)
- 049 29 or 40 or 48
- 050 20 and 49
- 051 50 not letter.pt.
- 052 51 not editorial.pt.
- 053 52 not news.pt.
- 054 53