# Appendixes

Appendix A. Search Strategy: MEDLINE and HealthSTAR for Intervention Studies

Appendix B. Search Strategy: MEDLINE AND HealthSTAR for Observational Studies

Appendix C. Search Strategy: CINAHL for Intervention Studies

Appendix D. Search Strategy: CINAHL for Observational Studies

Appendix E. Search Strategy: EMBASE for Intervention Studies

Appendix F. Search Strategy: EMBASE for Observational Studies

Appendix G. Relevance Form: Weaning from Mechanical Ventilation

Appendix H. Selection Criteria for Articles About Weaning

Appendix I. Extraction Form for General Characteristics fo All Studies

Appendix J. Extraction Form for Randomized Clinical Trials

Appendix K. Extraction Form for Nonrandomized Controlled Clinical Trials

Appendix L. Extraction Form for Observational Studies

Appendix M. Acronyms and Abbreviations