# References

1 Institute of Medicine of the National Academies. (2005). Dietary reference intakes for energy, carbohydrate, fiber, fat, fatty acids, cholesterol, protein, and amino acids / Panel on Macronutrients, Panel on the Definition of Dietary Fiber, Subcommittee on Upper Reference Levels of Nutrients, Subcommittee on Interpretation and Uses of Dietary Reference Intakes, and the Standing Committee on the Scientific Evaluation of Dietary Reference Intakes, Food and Nutrition Board.
2 Lewin GA, Schachter HM, Yuen D, et al. (2005). Effects of omega-3 fatty acids on child and maternal health.
3 Gould JF, Makrides M, Colombo J, et al. (2014). Randomized controlled trial of maternal omega-3 long-chain PUFA supplementation during pregnancy and early childhood development of attention, working memory, and inhibitory control. Am J Clin Nutr.
4 Schoeller DA, Thomas D, Archer E, et al. (2013). Self-report-based estimates of energy intake offer an inadequate basis for scientific conclusions. Am J Clin Nutr.
5 Archer E, Hand GA, Blair SN. (2013). Validity of US Nutritional Surveillance: National Health and Nutrition Examination Survey Caloric Energy Intake Data, 1971-2010. PLoS One.
6 Fekete K, Marosvolgyi T, Jakobik V, et al. (2009). Methods of assessment of n-3 long-chain polyunsaturated fatty acid status in humans: a systematic review. Am J Clin Nutr.
7 Serra-Majem L, Nissensohn M, Overby NC, et al. (2012). Dietary methods and biomarkers of omega 3 fatty acids: a systematic review. Br J Nutr.
8 Hill AB. (1965). The Environment and Disease: Association or Causation?. Proc R Soc Med.
9 (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
10 American College of Obstetricians, Gynecologists. Committee on Obstetric, Practice. (2010). Committee opinion no. 453: Screening for depression during and after pregnancy. Obstet Gynecol.
11 Higgins JP, Altman DG, Gotzsche PC, et al. (2011). The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ.
12 Wells G, Shea B, O'Connell J, et al. (2010). The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis.
13 Lichtenstein AH, Yetley EA, Lau J. (2008). Application of systematic review methodology to the field of nutrition. J Nutr.
14 Chung M, Balk EM, Ip S, et al. (2009). Reporting of systematic reviews of micronutrients and health: a critical appraisal. Am J Clin Nutr.
15 Newberry SJ, Chung M, Shekelle PG, et al. (2014). Vitamin D and Calcium: A Systematic Review of Health Outcomes (Update).
16 Chou R, Aronson N, Atkins D, et al. (2008). Assessing Harms When Comparing Medical Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
17 Hartung J. (1999). An alternative method for meta-analysis. Biometrical Journal.
18 Hartung J, Knapp G. (2001). A refined method for the meta-analysis of controlled clinical trials with binary outcome. Stat Med.
19 Sidik K, Jonkman JN. (2006). Robust variance estimation for random effects meta-analysis. Computational Statistics & Data Analysis.
20 Sánchez-Meca J, Marín-Martínez F. (2008). Confidence intervals for the overall effect size in random-effects meta-analysis. Psychol Methods.
21 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
22 R Core Team. (2015). R: A language and environment for statistical computing.
23 Shekelle PG, Motala A, Johnsen B, et al. (2014). Assessment of a method to detect signals for updating systematic reviews. Syst Rev.
24 Hamling J, Lee P, Weitkunat R, et al. (2008). Facilitating meta-analyses by deriving relative effect and precision estimates for alternative comparisons from a set of estimates presented by exposure level or disease category. Stat Med.
25 Ahmadzai N, Newberry SJ, Maglione MA, et al. (2013). A surveillance system to assess the need for updating systematic reviews. Syst Rev.
26 Greenland S, Longnecker MP. (1992). Methods for trend estimation from summarized dose-response data, with applications to meta-analysis. Am J Epidemiol.
27 Orsini N, Li R, Wolk A, et al. (2012). Meta-analysis for linear and nonlinear dose-response relations: examples, an evaluation of approximations, and software. Am J Epidemiol.
28 Olsen SF, Secher NJ, Tabor A, et al. (2000). Randomised clinical trials of fish oil supplementation in high risk pregnancies. Fish Oil Trials In Pregnancy (FOTIP) Team. BJOG.
29 Harper M, Thom E, Klebanoff MA, et al. (2010). Omega-3 fatty acid supplementation to prevent recurrent preterm birth: a randomized controlled trial. Obstet Gynecol.
30 Pietrantoni E, Del Chierico F, Rigon G, et al. (2014). Docosahexaenoic acid supplementation during pregnancy: a potential tool to prevent membrane rupture and preterm labor. Int J Mol Sci.
31 Carlson SE, Colombo J, Gajewski BJ, et al. (2013). DHA supplementation and pregnancy outcomes. Am J Clin Nutr.
32 Ramakrishnan U, Stein AD, Parra-Cabrera S, et al. (2010). Effects of docosahexaenoic acid supplementation during pregnancy on gestational age and size at birth: randomized, double-blind, placebo-controlled trial in Mexico. Food Nutr Bull.
33 Stein AD, Wang M, Rivera JA, et al. (2012). Auditory- and visual-evoked potentials in Mexican infants are not affected by maternal supplementation with 400 mg/d docosahexaenoic acid in the second half of pregnancy. J Nutr.
34 Stein AD, Wang M, Martorell R, et al. (2011). Growth to age 18 months following prenatal supplementation with docosahexaenoic acid differs by maternal gravidity in Mexico. J Nutr.
35 Makrides M, Gibson RA, McPhee AJ, et al. (2010). Effect of DHA supplementation during pregnancy on maternal depression and neurodevelopment of young children: a randomized controlled trial. JAMA.
36 van Goor SA, Dijck-Brouwer DA, Doornbos B, et al. (2010). Supplementation of DHA but not DHA with arachidonic acid during pregnancy and lactation influences general movement quality in 12-week-old term infants. Br J Nutr.
37 Hauner H, Much D, Vollhardt C, et al. (2012). Effect of reducing the n-6:n-3 long-chain PUFA ratio during pregnancy and lactation on infant adipose tissue growth within the first year of life: an open-label randomized controlled trial. Am J Clin Nutr.
38 Courville AB, Harel O, Lammi-Keefe CJ. (2011). Consumption of a DHA-containing functional food during pregnancy is associated with lower infant ponderal index and cord plasma insulin concentration. Br J Nutr.
39 Judge MP, Harel O, Lammi-Keefe CJ. (2007). Maternal consumption of a docosahexaenoic acid-containing functional food during pregnancy: benefit for infant performance on problem-solving but not on recognition memory tasks at age 9 mo. Am J Clin Nutr.
40 Judge MP, Cong X, Harel O, et al. (2012). Maternal consumption of a DHA-containing functional food benefits infant sleep patterning: an early neurodevelopmental measure. Early Hum Dev.
41 Lucia Bergmann R, Bergmann KE, Haschke-Becher E, et al. (2007). Does maternal docosahexaenoic acid supplementation during pregnancy and lactation lower BMI in late infancy?. J Perinat Med.
42 Mozurkewich EL, Clinton CM, Chilimigras JL, et al. (2013). The Mothers, Omega-3, and Mental Health Study: a double-blind, randomized controlled trial. Am J Obstet Gynecol.
43 Min Y, Djahanbakhch O, Hutchinson J, et al. (2014). Effect of docosahexaenoic acid-enriched fish oil supplementation in pregnant women with Type 2 diabetes on membrane fatty acids and fetal body composition--double-blinded randomized placebo-controlled trial. Diabet Med.
44 Dunstan JA, Simmer K, Dixon G, et al. (2008). Cognitive assessment of children at age 2(1/2) years after maternal fish oil supplementation in pregnancy: a randomised controlled trial. Archives of Disease in Childhood Fetal & Neonatal Edition.
45 Knudsen VK, Hansen HS, Osterdal ML, et al. (2006). Fish oil in various doses or flax oil in pregnancy and timing of spontaneous delivery: a randomised controlled trial. BJOG.
46 Oken E, Kleinman KP, Olsen SF, et al. (2004). Associations of seafood and elongated n-3 fatty acid intake with fetal growth and length of gestation: results from a US pregnancy cohort. Am J Epidemiol.
47 Badart-Smook A, van Houwelingen AC, Al MD, et al. (1997). Fetal growth is associated positively with maternal intake of riboflavin and negatively with maternal intake of linoleic acid. J Am Diet Assoc.
48 Molto-Puigmarti C, van Dongen MC, Dagnelie PC, et al. (2014). Maternal but not fetal FADS gene variants modify the association between maternal long-chain PUFA intake in pregnancy and birth weight. J Nutr.
49 Klebanoff MA, Harper M, Lai Y, et al. (2011). Fish consumption, erythrocyte fatty acids, and preterm birth. Obstet Gynecol.
50 Dunstan JA, Mori TA, Barden A, et al. (2003). Fish oil supplementation in pregnancy modifies neonatal allergen-specific immune responses and clinical outcomes in infants at high risk of atopy: a randomized, controlled trial. J Allergy Clin Immunol.
51 Meldrum S, Dunstan JA, Foster JK, et al. (2015). Maternal fish oil supplementation in pregnancy: a 12 year follow-up of a randomised controlled trial. Nutrients.
52 Bergmann RL, Bergmann KE, Richter R, et al. (2012). Does docosahexaenoic acid (DHA) status in pregnancy have any impact on postnatal growth? Six-year follow-up of a prospective randomized double-blind monocenter study on low-dose DHA supplements. J Perinat Med.
53 Smithers LG, Gibson RA, Makrides M. (2011). Maternal supplementation with docosahexaenoic acid during pregnancy does not affect early visual development in the infant: a randomized controlled trial. Am J Clin Nutr.
54 Palmer DJ, Sullivan T, Gold MS, et al. (2012). Effect of n-3 long chain polyunsaturated fatty acid supplementation in pregnancy on infants' allergies in first year of life: randomised controlled trial. BMJ.
55 Zhou SJ, Yelland L, McPhee AJ, et al. (2012). Fish-oil supplementation in pregnancy does not reduce the risk of gestational diabetes or preeclampsia. Am J Clin Nutr.
56 Palmer DJ, Sullivan T, Gold MS, et al. (2013). Randomized controlled trial of fish oil supplementation in pregnancy on childhood allergies. Allergy.
57 Makrides M, Gould JF, Gawlik NR, et al. (2014). Four-year follow-up of children born to women in a randomized trial of prenatal DHA supplementation. JAMA.
58 Imhoff-Kunsch B, Stein AD, Martorell R, et al. (2011). Prenatal docosahexaenoic acid supplementation and infant morbidity: randomized controlled trial. Pediatrics.
59 Escamilla-Nunez MC, Barraza-Villarreal A, Hernandez-Cadena L, et al. (2014). Omega-3 fatty acid supplementation during pregnancy and respiratory symptoms in children. Chest.
60 Gonzalez-Casanova I, Stein AD, Hao W, et al. (2015). Prenatal Supplementation with Docosahexaenoic Acid Has No Effect on Growth through 60 Months of Age. J Nutr.
61 Ramakrishnan U, Stinger A, DiGirolamo AM, et al. (2015). Prenatal Docosahexaenoic Acid Supplementation and Offspring Development at 18 Months: Randomized Controlled Trial. PLoS One.
62 Bouwstra H, Dijck-Brouwer DA, Wildeman JA, et al. (2003). Long-chain polyunsaturated fatty acids have a positive effect on the quality of general movements of healthy term infants. Am J Clin Nutr.
63 Bouwstra H, Dijck-Brouwer DA, Boehm G, et al. (2005). Long-chain polyunsaturated fatty acids and neurological developmental outcome at 18 months in healthy term infants. Acta Paediatr.
64 de Jong C, Kikkert HK, Fidler V, et al. (2010). The Groningen LCPUFA study: no effect of postnatal long-chain polyunsaturated fatty acids in healthy term infants on neurological condition at 9 years. Br J Nutr.
65 de Jong C, Kikkert HK, Fidler V, et al. (2012). Effects of long-chain polyunsaturated fatty acid supplementation of infant formula on cognition and behaviour at 9 years of age. Dev Med Child Neurol.
66 van Goor SA, Dijck-Brouwer DA, Erwich JJ, et al. (2011). The influence of supplemental docosahexaenoic and arachidonic acids during pregnancy and lactation on neurodevelopment at eighteen months. Prostaglandins Leukot Essent Fatty Acids.
67 Al MD, van Houwelingen AC, Badart-Smook A, et al. (1995). The essential fatty acid status of mother and child in pregnancy-induced hypertension: a prospective longitudinal study. Am J Obstet Gynecol.
68 Clausen T, Slott M, Solvoll K, et al. (2001). High intake of energy, sucrose, and polyunsaturated fatty acids is associated with increased risk of preeclampsia. Am J Obstet Gynecol.
69 Oken E, Ning Y, Rifas-Shiman SL, et al. (2007). Diet during pregnancy and risk of preeclampsia or gestational hypertension. Ann Epidemiol.
70 Olafsdottir AS, Skuladottir GV, Thorsdottir I, et al. (2006). Relationship between high consumption of marine fatty acids in early pregnancy and hypertensive disorders in pregnancy. BJOG.
71 Lim WY, Chong M, Calder PC, et al. (2015). Relations of plasma polyunsaturated Fatty acids with blood pressures during the 26th and 28th week of gestation in women of Chinese, Malay, and Indian ethnicity. Medicine.
72 Muthayya S, Dwarkanath P, Thomas T, et al. (2009). The effect of fish and omega-3 LCPUFA intake on low birth weight in Indian pregnant women. Eur J Clin Nutr.
73 Smits LJ, Elzenga HM, Gemke RJ, et al. (2013). The association between interpregnancy interval and birth weight: what is the role of maternal polyunsaturated fatty acid status?. BMC Pregnancy Childbirth.
74 Gustafson KM, Carlson SE, Colombo J, et al. (2013). Effects of docosahexaenoic acid supplementation during pregnancy on fetal heart rate and variability: a randomized clinical trial. Prostaglandins Leukotrienes & Essential Fatty Acids.
75 Mulder KA, King DJ, Innis SM. (2014). Omega-3 fatty acid deficiency in infants before birth identified using a randomized trial of maternal DHA supplementation in pregnancy. PLoS ONE.
76 Helland IB, Smith L, Blomen B, et al. (2008). Effect of supplementing pregnant and lactating mothers with n-3 very-long-chain fatty acids on children's IQ and body mass index at 7 years of age. Pediatrics.
77 Tofail F, Kabir I, Hamadani JD, et al. (2006). Supplementation of fish-oil and soy-oil during pregnancy and psychomotor development of infants. Journal of Health, Population & Nutrition.
78 Miles EA, Noakes PS, Kremmyda LS, et al. (2011). The Salmon in Pregnancy Study: study design, subject characteristics, maternal fish and marine n-3 fatty acid intake, and marine n-3 fatty acid status in maternal and umbilical cord blood. Am J Clin Nutr.
79 Linnamaa P, Savolainen J, Koulu L, et al. (2010). Blackcurrant seed oil for prevention of atopic dermatitis in newborns: a randomized, double-blind, placebo-controlled trial. Clin Exp Allergy.
80 Drouillet P, Forhan A, De Lauzon-Guillain B, et al. (2009). Maternal fatty acid intake and fetal growth: evidence for an association in overweight women. The ‘EDEN mother-child’ cohort (study of pre- and early postnatal determinants of the child's development and health). Br J Nutr.
81 Brantsaeter AL, Birgisdottir BE, Meltzer HM, et al. (2012). Maternal seafood consumption and infant birth weight, length and head circumference in the Norwegian Mother and Child Cohort Study. Br J Nutr.
82 Olafsdottir AS, Magnusardottir AR, Thorgeirsdottir H, et al. (2005). Relationship between dietary intake of cod liver oil in early pregnancy and birthweight. BJOG.
83 Much D, Brunner S, Vollhardt C, et al. (2013). Effect of dietary intervention to reduce the n-6/n-3 fatty acid ratio on maternal and fetal fatty acid profile and its relation to offspring growth and body composition at 1 year of age. Eur J Clin Nutr.
84 Dirix CE, Kester AD, Hornstra G. (2009). Associations between neonatal birth dimensions and maternal essential and trans fatty acid contents during pregnancy and at delivery. Br J Nutr.
85 Mohanty AF, Thompson ML, Burbacher TM, et al. (2015). Periconceptional Seafood Intake and Fetal Growth. Paediatr Perinat Epidemiol.
86 Helland IB, Saugstad OD, Smith L, et al. (2001). Similar effects on infants of n-3 and n-6 fatty acids supplementation to pregnant and lactating women. Pediatrics.
87 Helland IB, Smith L, Saarem K, et al. (2003). Maternal supplementation with very-long-chain n-3 fatty acids during pregnancy and lactation augments children's IQ at 4 years of age. Pediatrics.
88 Noakes PS, Vlachava M, Kremmyda LS, et al. (2012). Increased intake of oily fish in pregnancy: effects on neonatal immune responses and on clinical outcomes in infants at 6 mo. Am J Clin Nutr.
89 Bernard JY, De Agostini M, Forhan A, et al. (2013). The dietary n6:n3 fatty acid ratio during pregnancy is inversely associated with child neurodevelopment in the EDEN mother-child cohort. J Nutr.
90 Doornbos B, van Goor SA, Dijck-Brouwer DA, et al. (2009). Supplementation of a low dose of DHA or DHA+AA does not prevent peripartum depressive symptoms in a small population based sample. Prog Neuropsychopharmacol Biol Psychiatry.
91 Judge MP, Beck CT, Durham H, et al. (2014). Pilot trial evaluating maternal docosahexaenoic acid consumption during pregnancy: Decreased postpartum depressive symptomatology. International Journal of Nursing Sciences.
92 Strom M, Mortensen EL, Halldorsson TI, et al. (2009). Fish and long-chain n-3 polyunsaturated fatty acid intakes during pregnancy and risk of postpartum depression: a prospective study based on a large national birth cohort. Am J Clin Nutr.
93 Miyake Y, Sasaki S, Yokoyama T, et al. (2006). Risk of postpartum depression in relation to dietary fish and fat intake in Japan: The Osaka Maternal and Child Health Study. Psychol Med.
94 Leung BM, Kaplan BJ, Field CJ, et al. (2013). Prenatal micronutrient supplementation and postpartum depressive symptoms in a pregnancy cohort. BMC Pregnancy Childbirth.
95 Chong MF, Ong YL, Calder PC, et al. (2015). Long-Chain polyunsaturated fatty acid status during pregnancy and maternal mental health in pregnancy and the postpartum period: results from the GUSTO study. J Clin Psychiatry.
96 Sallis H, Steer C, Paternoster L, et al. (2014). Perinatal depression and omega-3 fatty acids: a Mendelian randomisation study. J Affect Disord.
97 Parker G, Hegarty B, Granville-Smith I, et al. (2015). Is essential fatty acid status in late pregnancy predictive of post-natal depression?. Acta Psychiatr Scand.
98 Llorente AM, Jensen CL, Voigt RG, et al. (2003). Effect of maternal docosahexaenoic acid supplementation on postpartum depression and information processing. Am J Obstet Gynecol.
99 Isaacs EB, Ross S, Kennedy K, et al. (2011). 10-year cognition in preterms after random assignment to fatty acid supplementation in infancy. Pediatrics.
100 Malcolm CA, McCulloch DL, Montgomery C, et al. (2003). Maternal docosahexaenoic acid supplementation during pregnancy and visual evoked potential development in term infants: a double blind, prospective, randomised trial. Archives of Disease in Childhood Fetal & Neonatal Edition.
101 Much D, Brunner S, Vollhardt C, et al. (2013). Breast milk fatty acid profile in relation to infant growth and body composition: results from the INFAT study. Pediatr Res.
102 Lauritzen L, Hoppe C, Straarup EM, et al. (2005). Maternal fish oil supplementation in lactation and growth during the first 2.5 years of life. Pediatr Res.
103 Scholtens S, Wijga AH, Smit HA, et al. (2009). Long-chain polyunsaturated fatty acids in breast milk and early weight gain in breast-fed infants. Br J Nutr.
104 Smithers LG, Gibson RA, McPhee A, et al. (2008). Higher dose of docosahexaenoic acid in the neonatal period improves visual acuity of preterm infants: results of a randomized controlled trial. Am J Clin Nutr.
105 Collins CT, Makrides M, Gibson RA, et al. (2011). Pre- and post-term growth in pre-term infants supplemented with higher-dose DHA: a randomised controlled trial. Br J Nutr.
106 Groh-Wargo S, Jacobs J, Auestad N, et al. (2005). Body composition in preterm infants who are fed long-chain polyunsaturated fatty acids: a prospective, randomized, controlled trial. Pediatr Res.
107 Henriksen C, Haugholt K, Lindgren M, et al. (2008). Improved cognitive development among preterm infants attributable to early supplementation of human milk with docosahexaenoic acid and arachidonic acid. Pediatrics.
108 Clandinin MT, Van Aerde JE, Merkel KL, et al. (2005). Growth and development of preterm infants fed infant formulas containing docosahexaenoic acid and arachidonic acid. J Pediatr.
109 Lagemaat M, Rotteveel J, Muskiet FA, et al. (2011). Post term dietary-induced changes in DHA and AA status relate to gains in weight, length, and head circumference in preterm infants. Prostaglandins Leukot Essent Fatty Acids.
110 Sala-Vila A, Castellote AI, Campoy C, et al. (2004). The source of long-chain PUFA in formula supplements does not affect the fatty acid composition of plasma lipids in full-term infants. J Nutr.
111 Birch EE, Castaneda YS, Wheaton DH, et al. (2005). Visual maturation of term infants fed long-chain polyunsaturated fatty acid-supplemented or control formula for 12 mo. Am J Clin Nutr.
112 Field CJ, Van Aerde JE, Robinson LE, et al. (2008). Effect of providing a formula supplemented with long-chain polyunsaturated fatty acids on immunity in full-term neonates. Br J Nutr.
113 Fleddermann M, Demmelmair H, Grote V, et al. (2014). Infant formula composition affects energetic efficiency for growth: the BeMIM study, a randomized controlled trial. Clin Nutr.
114 Hoffman D, Ziegler E, Mitmesser SH, et al. (2008). Soy-based infant formula supplemented with DHA and ARA supports growth and increases circulating levels of these fatty acids in infants. Lipids.
115 Currie LM, Tolley EA, Thodosoff JM, et al. (2015). Long chain polyunsaturated fatty acid supplementation in infancy increases length- and weight-for-age but not BMI to 6 years when controlling for effects of maternal smoking. Prostaglandins Leukot Essent Fatty Acids.
116 Makrides M, Gibson RA, McPhee AJ, et al. (2009). Neurodevelopmental outcomes of preterm infants fed high-dose docosahexaenoic acid: a randomized controlled trial. JAMA.
117 Smithers LG, Collins CT, Simmonds LA, et al. (2010). Feeding preterm infants milk with a higher dose of docosahexaenoic acid than that used in current practice does not influence language or behavior in early childhood: a follow-up study of a randomized controlled trial. Am J Clin Nutr.
118 Manley BJ, Makrides M, Collins CT, et al. (2011). High-dose docosahexaenoic acid supplementation of preterm infants: respiratory and allergy outcomes. Pediatrics.
119 Atwell K, Collins CT, Sullivan TR, et al. (2013). Respiratory hospitalisation of infants supplemented with docosahexaenoic acid as preterm neonates. J Paediatr Child Health.
120 Collins CT, Gibson RA, Anderson PJ, et al. (2015). Neurodevelopmental outcomes at 7 years' corrected age in preterm infants who were fed high-dose docosahexaenoic acid to term equivalent: a follow-up of a randomised controlled trial. BMJ Open.
121 Birch EE, Carlson SE, Hoffman DR, et al. (2010). The DIAMOND (DHA Intake And Measurement Of Neural Development) Study: a double-masked, randomized controlled clinical trial of the maturation of infant visual acuity as a function of the dietary level of docosahexaenoic acid. Am J Clin Nutr.
122 Drover JR, Hoffman DR, Castaneda YS, et al. (2011). Cognitive function in 18-month-old term infants of the DIAMOND study: a randomized, controlled clinical trial with multiple dietary levels of docosahexaenoic acid. Early Hum Dev.
123 Drover JR, Felius J, Hoffman DR, et al. (2012). A randomized trial of DHA intake during infancy: school readiness and receptive vocabulary at 2-3.5 years of age. Early Hum Dev.
124 Colombo J, Carlson SE, Cheatham CL, et al. (2013). Long-term effects of LCPUFA supplementation on childhood cognitive outcomes. Am J Clin Nutr.
125 Westerberg AC, Schei R, Henriksen C, et al. (2011). Attention among very low birth weight infants following early supplementation with docosahexaenoic and arachidonic acid. Acta Paediatr.
126 Almaas AN, Tamnes CK, Nakstad B, et al. (2015). Long-chain polyunsaturated fatty acids and cognition in VLBW infants at 8 years: an RCT. Pediatrics.
127 Lauritzen L, Jorgensen MH, Mikkelsen TB, et al. (2004). Maternal fish oil supplementation in lactation: Effect on visual acuity and n-3 fatty acid content of infant erythrocytes. Lipids.
128 Lauritzen L, Jorgensen MH, Olsen SF, et al. (2005). Maternal fish oil supplementation in lactation: effect on developmental outcome in breast-fed infants. Reprod Nutr Dev.
129 Cheatham CL, Nerhammer AS, Asserhoj M, et al. (2011). Fish oil supplementation during lactation: Effects on cognition and behavior at 7 years of age. Lipids.
130 Escolano-Margarit MV, Ramos R, Beyer J, et al. (2011). Prenatal DHA status and neurological outcome in children at age 5.5 years are positively associated. J Nutr.
131 Sun Y, Vestergaard M, Christensen J, et al. (2010). Intake of marine n-3 fatty acids during pregnancy and risk for epilepsy in the offspring: a population-based cohort study. Epilepsy Res.
132 Valent F, Mariuz M, Bin M, et al. (2013). Associations of prenatal mercury exposure from maternal fish consumption and polyunsaturated fatty acids with child neurodevelopment: a prospective cohort study in Italy. J Epidemiol.
133 Bouwstra H, Dijck-Brouwer DJ, Decsi T, et al. (2006). Relationship between umbilical cord essential fatty acid content and the quality of general movements of healthy term infants at 3 months. Pediatr Res.
134 Bakker EC, Hornstra G, Blanco CE, et al. (2009). Relationship between long-chain polyunsaturated fatty acids at birth and motor function at 7 years of age. Eur J Clin Nutr.
135 Jensen CL, Voigt RG, Llorente AM, et al. (2010). Effects of early maternal docosahexaenoic acid intake on neuropsychological status and visual acuity at five years of age of breast-fed term infants. J Pediatr.
136 Jensen CL, Voigt RG, Prager TC, et al. (2005). Effects of maternal docosahexaenoic acid intake on visual function and neurodevelopment in breastfed term infants. Am J Clin Nutr.
137 Fang PC, Kuo HK, Huang CB, et al. (2005). The effect of supplementation of docosahexaenoic acid and arachidonic acid on visual acuity and neurodevelopment in larger preterm infants. Chang Gung Med J.
138 Unay B, Sarici SU, Ulas UH, et al. (2004). Nutritional effects on auditory brainstem maturation in healthy term infants. Archives of Disease in Childhood Fetal & Neonatal Edition.
139 Agostoni C, Zuccotti GV, Radaelli G, et al. (2009). Docosahexaenoic acid supplementation and time at achievement of gross motor milestones in healthy infants: a randomized, prospective, double-blind, placebo-controlled trial. Am J Clin Nutr.
140 Meldrum SJ, D'Vaz N, Simmer K, et al. (2012). Effects of high-dose fish oil supplementation during early infancy on neurodevelopment and language: a randomised controlled trial. Br J Nutr.
141 Campoy C, Escolano-Margarit MV, Ramos R, et al. (2011). Effects of prenatal fish-oil and 5-methyltetrahydrofolate supplementation on cognitive development of children at 6.5 y of age. Am J Clin Nutr.
142 D'Vaz N, Meldrum SJ, Dunstan JA, et al. (2012). Postnatal fish oil supplementation in high-risk infants to prevent allergy: randomized controlled trial. Pediatrics.
143 Julvez J, Guxens M, Carsin AE, et al. (2014). A cohort study on full breastfeeding and child neuropsychological development: The role of maternal social, psychological, and nutritional factors. Dev Med Child Neurol.
144 Guxens M, Mendez MA, Molto-Puigmarti C, et al. (2011). Breastfeeding, long-chain polyunsaturated fatty acids in colostrum, and infant mental development. Pediatrics.
145 Innis SM, Friesen RW. (2008). Essential n-3 fatty acids in pregnant women and early visual acuity maturation in term infants. Am J Clin Nutr.
146 Birch EE, Garfield S, Castaneda Y, et al. (2007). Visual acuity and cognitive outcomes at 4 years of age in a double-blind, randomized trial of long-chain polyunsaturated fatty acid-supplemented infant formula. Early Hum Dev.
147 Carlson SE, Werkman SH, Rhodes PG, et al. (1993). Visual-acuity development in healthy preterm infants: effect of marine-oil supplementation. Am J Clin Nutr.
148 Carlson SE, Werkman SH, Tolley EA. (1996). Effect of long-chain n-3 fatty acid supplementation on visual acuity and growth of preterm infants with and without bronchopulmonary dysplasia. Am J Clin Nutr.
149 van Wezel-Meijler G, van der Knaap MS, Huisman J, et al. (2002). Dietary supplementation of long-chain polyunsaturated fatty acids in preterm infants: effects on cerebral maturation. Acta Paediatr.
150 Birch EE, Hoffman DR, Uauy R, et al. (1998). Visual acuity and the essentiality of docosahexaenoic acid and arachidonic acid in the diet of term infants. Pediatr Res.
151 Auestad N, Montalto MB, Hall RT, et al. (1997). Visual acuity, erythrocyte fatty acid composition, and growth in term infants fed formulas with long chain polyunsaturated fatty acids for one year. Ross Pediatric Lipid Study. Pediatr Res.
152 Birch EE, Hoffman DR, Castaneda YS, et al. (2002). A randomized controlled trial of long-chain polyunsaturated fatty acid supplementation of formula in term infants after weaning at 6 wk of age. Am J Clin Nutr.
153 Hoffman DR, Birch EE, Castaneda YS, et al. (2003). Visual function in breast-fed term infants weaned to formula with or without long-chain polyunsaturates at 4 to 6 months: a randomized clinical trial. J Pediatr.
154 Werkman SH, Carlson SE. (1996). A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until nine months. Lipids.
155 Gibson RA, Neumann MA, Makrides M. (1997). Effect of increasing breast milk docosahexaenoic acid on plasma and erythrocyte phospholipid fatty acids and neural indices of exclusively breast fed infants. Eur J Clin Nutr.
156 Agostoni C, Marangoni F, Giovannini M, et al. (2001). Prolonged breast-feeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol.
157 O'Connor DL, Hall R, Adamkin D, et al. (2001). Growth and development in preterm infants fed long-chain polyunsaturated fatty acids: a prospective, randomized controlled trial. Pediatrics.
158 Fewtrell MS, Morley R, Abbott RA, et al. (2002). Double-blind, randomized trial of long-chain polyunsaturated fatty acid supplementation in formula fed to preterm infants. Pediatrics.
159 Fewtrell MS, Abbott RA, Kennedy K, et al. (2004). Randomized, double-blind trial of long-chain polyunsaturated fatty acid supplementation with fish oil and borage oil in preterm infants. J Pediatr.
160 Carlson SE, Werkman SH. (1996). A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until two months. Lipids.
161 Lucas A, Stafford M, Morley R, et al. (1999). Efficacy and safety of long-chain polyunsaturated fatty acid supplementation of infant-formula milk: a randomised trial. Lancet.
162 Keim SA, Daniels JL, Siega-Riz AM, et al. (2012). Breastfeeding and long-chain polyunsaturated fatty acid intake in the first 4 post-natal months and infant cognitive development: an observational study. Matern Child Nutr.
163 Bakker EC, Ghys AJ, Kester AD, et al. (2003). Long-chain polyunsaturated fatty acids at birth and cognitive function at 7 y of age. Eur J Clin Nutr.
164 Steer CD, Lattka E, Koletzko B, et al. (2013). Maternal fatty acids in pregnancy, FADS polymorphisms, and child intelligence quotient at 8 y of age. Am J Clin Nutr.
165 Brew BK, Toelle BG, Webb KL, et al. (2015). Omega-3 supplementation during the first 5 years of life and later academic performance: a randomised controlled trial. Eur J Clin Nutr.
166 Mihrshahi S, Peat JK, Marks GB, et al. (2003). Eighteen-month outcomes of house dust mite avoidance and dietary fatty acid modification in the Childhood Asthma Prevention Study (CAPS). J Allergy Clin Immunol.
167 Peat JK, Mihrshahi S, Kemp AS, et al. (2004). Three-year outcomes of dietary fatty acid modification and house dust mite reduction in the Childhood Asthma Prevention Study. J Allergy Clin Immunol.
168 Marks GB, Mihrshahi S, Kemp AS, et al. (2006). Prevention of asthma during the first 5 years of life: a randomized controlled trial. J Allergy Clin Immunol.
169 Toelle BG, Ng KK, Crisafulli D, et al. (2010). Eight-year outcomes of the Childhood Asthma Prevention Study. J Allergy Clin Immunol.
170 Willatts P, Forsyth S, Agostoni C, et al. (2013). Effects of long-chain PUFA supplementation in infant formula on cognitive function in later childhood. Am J Clin Nutr.
171 Lyall K, Munger KL, O'Reilly EJ, et al. (2013). Maternal dietary fat intake in association with autism spectrum disorders. Am J Epidemiol.
172 Furuhjelm C, Warstedt K, Fageras M, et al. (2011). Allergic disease in infants up to 2 years of age in relation to plasma omega-3 fatty acids and maternal fish oil supplementation in pregnancy and lactation. Pediatr Allergy Immunol.
173 Furuhjelm C, Warstedt K, Larsson J, et al. (2009). Fish oil supplementation in pregnancy and lactation may decrease the risk of infant allergy. Acta Paediatr.
174 Denburg JA, Hatfield HM, Cyr MM, et al. (2005). Fish oil supplementation in pregnancy modifies neonatal progenitors at birth in infants at risk of atopy. Pediatr Res.
175 Wijga AH, van Houwelingen AC, Kerkhof M, et al. (2006). Breast milk fatty acids and allergic disease in preschool children: the Prevention and Incidence of Asthma and Mite Allergy birth cohort study. J Allergy Clin Immunol.
176 Newson RB, Shaheen SO, Henderson AJ, et al. (2004). Umbilical cord and maternal blood red cell fatty acids and early childhood wheezing and eczema. J Allergy Clin Immunol.
177 Standl M, Demmelmair H, Koletzko B, et al. (2014). Cord blood LC-PUFA composition and allergic diseases during the first 10 yr. Results from the LISAplus study. Pediatr Allergy Immunol.
178 Thijs C, Muller A, Rist L, et al. (2011). Fatty acids in breast milk and development of atopic eczema and allergic sensitisation in infancy. Allergy.
179 Notenboom ML, Mommers M, Jansen EH, et al. (2011). Maternal fatty acid status in pregnancy and childhood atopic manifestations: KOALA Birth Cohort Study. Clin Exp Allergy.
180 Nwaru BI, Erkkola M, Lumia M, et al. (2012). Maternal intake of fatty acids during pregnancy and allergies in the offspring. Br J Nutr.
181 Saito K, Yokoyama T, Miyake Y, et al. (2010). Maternal meat and fat consumption during pregnancy and suspected atopic eczema in Japanese infants aged 3-4 months: the Osaka Maternal and Child Health Study. Pediatr Allergy Immunol.
182 Miyake Y, Sasaki S, Tanaka K, et al. (2009). Maternal fat consumption during pregnancy and risk of wheeze and eczema in Japanese infants aged 16-24 months: the Osaka Maternal and Child Health Study. Thorax.
183 Miyake Y, Tanaka K, Okubo H, et al. (2013). Maternal fat intake during pregnancy and wheeze and eczema in Japanese infants: the Kyushu Okinawa Maternal and Child Health Study. Ann Epidemiol.
184 Morales E, Garcia-Esteban R, Guxens M, et al. (2012). Effects of prolonged breastfeeding and colostrum fatty acids on allergic manifestations and infections in infancy. Clin Exp Allergy.
185 Yu YM, Chan YH, Calder PC, et al. (2015). Maternal PUFA status and offspring allergic diseases up to the age of 18 months. Br J Nutr.
186 Pike KC, Calder PC, Inskip HM, et al. (2012). Maternal plasma phosphatidylcholine fatty acids and atopy and wheeze in the offspring at age of 6 years. Clin Dev Immunol.
187 Olsen SF, Osterdal ML, Salvig JD, et al. (2008). Fish oil intake compared with olive oil intake in late pregnancy and asthma in the offspring: 16 y of registry-based follow-up from a randomized controlled trial. Am J Clin Nutr.
188 Lumia M, Luukkainen P, Tapanainen H, et al. (2011). Dietary fatty acid composition during pregnancy and the risk of asthma in the offspring. Pediatr Allergy Immunol.