# Methods

The present review evaluates the effects ofn-3 FAs (including EPA, DHA, DPA, ALA, SDA, and n-3 biomarkers) on—and the associations between n-3 FA and—maternal and child health outcomes. The Evidence-based Practice Center (EPC) conducted the review of the published scientific literature using established methods as outlined in the Agency for Healthcare Research and Quality (AHRQ)'s Methods Guide for Comparative Effectiveness Reviews.^9^

This review was conducted in parallel with a systematic review of n-3 FA and cardiovascular disease, conducted by another EPC. Several aspects of the reviews are being coordinated, including eligibility criteria regarding interventions and exposures, search strategies, structure of the reviews, and assessments of the studies' risk of bias, strength of the bodies of evidence, and abstraction of study characteristics needed to assess causality.

## Topic Refinement and Review Protocol

We convened a Technical Expert Panel (TEP) to help refine the research questions and protocol. The TEP included international experts in n-3 FA research, academic pediatricians, an obstetrician-gynecologist who represents the American Congress of Obstetricians and Gynecologists, and a pediatrician who represents the American Academy of Pediatrics. Also included in the discussions with the TEP were the ODS Director of and a Senior Scientist and the AHRQ Task Order Officer. We discussed the Key Questions, analytic framework, study eligibility criteria, literature searches, and analysis plans. In addition, in separate discussions with the ODS representative and our TOO we considered how and whether to assess the concept of causality, particularly for the observational studies. After discussion of the Bradford Hill criteria and related issues regarding causality,^8^ we agreed to provide the study-level data for items that may be pertinent for users of this report to assess causality (this information is included in the Evidence tables in Appendixes C and D).

Furthermore, we had joint discussions with the Brown University EPC—which conducted the parallel report on n-3 FA and cardiovascular disease —and our TOO and the ODS representative to coordinate our protocols and processes. The protocol was entered into the PROSPERO register (registry number CRD42015020638).

## Literature Search

### Search Strategy

We modified the existing search strategies from the original report (see Appendix A) to include a complete set of terms for the new outcomes of interest based on searches we have conducted on these topics for previous reviews and consultation with colleagues. We conducted literature searches in Medline (Pubmed), Embase, the Cochrane Collection, Web of Science and CAB. For the topics of depression; ADHD; autism; and cognitive, neurological, and visual function development, we searched PsychInfo. We did not search for unpublished (grey) literature; however, a notice was published in the Federal Register requesting unpublished data from manufacturers of omega-3 fatty acid-fortified infant formulae and dietary supplements. Search dates for all topics were January 1, 2000 to August 24, 2015. For the newly added topics, we “reference mined” articles that we identified to determine whether any studies conducted and published prior to 2000 should be obtained and included. Search results were crosschecked with the list of studies included in the original report (as well as the list of prospective cohort studies excluded from the original report that must now be included) to ensure that no studies included in the original report are inadvertently included in the current report as “new” studies.

Appendix A displays the current complete search strategy.

## Inclusion and Exclusion Criteria

The current eligibility criteria are mostly similar to the criteria used in the original 2005 review. The populations are expanded to accommodate the expanded outcomes of interest. The interventions and exposures remain the same as those in the original report, with the addition of two n-3 FA (DPA and SDA). Included study designs have been modified slightly.

The Eligibility Criteria are outlined here according to the PICOT framework, with indications of the Key Questions to which they apply.

- Population(s):
  ○ Key Question (KQ) 1(Maternal exposures and outcomes)
    ▪ Healthy pregnant women (for outcomes of birth weight, intrauterine growth restriction/small for gestational age, duration of gestation, risk of pre-eclampsia, eclampsia, or pregnancy hypertension)
    ▪ Pregnant women with a history of pre-eclampsia, eclampsia, or pregnancy hypertension (only for outcome of risk of pre-eclampsia, eclampsia, or pregnancy hypertension)
    ▪ Pregnant women with a history of major depressive disorder or postpartum depression (only for the outcome of risk for peripartum depression)
  ○ Key Question 2 (In utero and postnatal (through the first year of life) exposures and outcomes)
    ▪ Healthy preterm or full term infants of healthy women/mothers whose n-3 fatty acid exposures were monitored during pregnancy
    ▪ Breastfed infants of healthy mothers whose n-3 fatty acid exposure was monitored and/or who participated in an n-3 fatty acid intervention during breastfeeding beginning at birth
    ▪ Healthy preterm or full term infants with and without family history of respiratory conditions (for outcomes related to atopic dermatitis, allergy, respiratory conditions) of mothers whose n-3 exposures were monitored during pregnancy and/or breastfeeding
    ▪ Healthy children or children with a family history of a respiratory disorder, a cognitive or visual development disorder, autism spectrum disorder, ADHD, or learning disabilities, age 0 to 18 years who participated in an n-3 fatty acid-supplemented infant formula intervention or an n-3 supplementation trial during infancy
  ○ Key Question 3 (Adverse events associated with n-3 interventions)
    ▪ Healthy pregnant women or pregnant women in the other categories described above
    ▪ Offspring of women enrolled in an n-3 fatty acid intervention during pregnancy
    ▪ Offspring of women whose exposure to n 3 fatty acids was assessed during pregnancy
    ▪ Children whose exposure to n-3 fatty acids (through breast milk, infant formula, or supplementation) was monitored during the first year of life
- Interventions/Exposures:
  ○ Interventions (KQ1, 2, 3 unless specified):
    ▪ N-3 fatty acid supplements (e.g., EPA, DHA, ALA, singly or in combination;
    ▪ N-3 fatty acid supplemented foods (e.g., eggs) with quantified n-3 content
    ▪ High-dose pharmaceutical grade n-3 fatty acids, e.g., Omacor®, Ropufa®, MaxEPA®, Efamed, Res-Q®, Epagis, Almarin, Coromega, Lovaza®, Vascepa® (icosapent ethyl)
      - Exclude doses of more than 6g/d, except for trials that report adverse events
    ▪ N-3 fatty acid fortified infant formulae (KQ2,3)
      - E.g., Enfamil® Lipil®; Gerber® Good Start DHA & ARA®; Similac® Advance®
      - N-3 fortified follow-up formulae
      - Exclude parenterally administered sources
    ▪ Marine oils, including fish oil, cod liver oil, and menhaden oil with quantified n-3 content
    ▪ Algal or other marine sources of omega-3 fatty acids with quantified n-3 content
  ○ Exposures (KQ1,2)
    ▪ Dietary n-3 fatty acids from foods if concentrations are quantified in food frequency questionnaires
    ▪ Breast milk n-3 fatty acids (KQ2)
    ▪ Biomarkers (EPA, DHA, ALA, DPA, SDA), including but not limited to the following:
      - Plasma fatty acids
      - Erythrocyte fatty acids
      - Adipocyte fatty acids.
- Comparators:
  ○ Inactive comparators:
    ▪ Placebo (KQ1, 2, 3)
    ▪ Non-fortified infant formula (KQ2)
  ○ Active comparators
    ▪ Different n-3 sources
    ▪ Different n-3 concentrations (KQ1, 2, 3)
    ▪ Alternative n-3 fortified infant formulae (KQ2)
    ▪ Soy-based infant formula (KQ2)
    ▪ Diet with different level of Vitamin E exposure
- Outcomes:
  ○ Maternal outcomes (KQ1)
    ▪ Blood pressure control
      - Incidence of gestational hypertension
      - Maternal blood pressure
      - Incidence of pre-eclampsia, eclampsia
    ▪ Peripartum depression
      - Incidence of antepartum depression^10^
      - Incidence of postpartum depression, e.g.,
        ○ Edinburgh Postnatal Depression scale
        ○ Structured Clinical Interview (SCI)
    ▪ Gestational length
      - Duration of gestation
      - Incidence of preterm birth
    ▪ Birth weight
      - Mean birth weight
      - Incidence of low birth weight/small for gestational age
  ○ Pediatric Outcomes (KQ2)
    ▪ Neurological/visual/cognitive development
      - Visual development, e.g.,
        ○ Visual evoked potential acuity
        ○ Behavioral visual acuity testing
          ▪ Teller's Acuity Card test and others
        ○ Electroretinography
      - Cognitive development, e.g.,
        ○ Bayley's Scale of Infant and Toddler Development Mental Development Index
        ○ Griffith Mental Developmental Scale
        ○ Kauffman Assessment Battery for Children
        ○ Neonatal Behavioral Assessment
        ○ Wechsler Scales
        ○ MacArthur Communicative Development Inventory
        ○ Fagan Test of Infant Intelligence
        ○ Ages and Stages Questionnaire
        ○ Stanford-Binet IQ
      - Neurological development
        ○ Electroencephalograms (EEGs) as measure of maturity
        ○ Psychomotor developmental index from Bayley's scales
        ○ Neurological/movement impairment assessment
        ○ Active sleep, quiet sleep, sleep-wake transition, wakefulness
        ○ Nerve conduction test
        ○ Latency Auditory evoked potential
    ▪ Risk for ADHD
      - Validated evaluation procedures
        ○ E.g., Wechsler Intelligence Scale for Children,
        ○ Behavioral rating scales, e.g., Connors, Vanderbilt, and Barkley scales
    ▪ Risk for Autism spectrum disorders
      - Validated evaluation procedures
        ○ E.g., Modified Checklist of Autism in Toddlers
    ▪ Risk for learning disabilities
      - Validated evaluation procedures
    ▪ Risk for atopic dermatitis
    ▪ Risk for allergies
      - Validated allergy assessment procedures, preferably challenge (skin prick test or validated blood tests accepted)
    ▪ Incidence of respiratory disorders
      - Spirometry in children 5 and over (peak expiratory flow rate [PEFR] and forced expiratory volume in 1 second [FEV_1_])
  ○ Key Question 3: Adverse effects of intervention(s)
    ▪ Incidence of specific adverse events reported in trials by study arm
- Timing:
  ○ Duration of intervention or follow-up
    ▪ Key Question 1,3 (maternal interventions/exposures):
      - Interventions implemented anytime during pregnancy but preferably during the first or second trimester
      - Follow-up duration is anytime during pregnancy (for maternal outcomes of pre/eclampsia or maternal hypertension); term (for outcomes related to birth weight, duration of pregnancy); or within the first 6 months postpartum (for the outcome of postpartum depression)
    ▪ Key Question 2, 3 (infant exposures):
      - Interventions implemented within one month of birth or exposures measured within 1 month of birth
      - Follow-up duration is 0 to 18 years
- Settings:
  ○ Community-dwelling individuals seen by primary care physicians or obstetricians in private or academic medical practices (KQ1, 3)
  ○ Community dwelling children seen in outpatient health care or educational settings (KQ2, 3)

We limited the study designs of interest to RCTs, prospective cohort studies, and nested case control studies (cross-sectional, retrospective cohort, and case study designs were excluded; studies must have measure of intake/exposure prior to outcome). Only peer-reviewed studies published in English language were included. Unpublished studies were not included.

To focus on studies of the highest relevance and quality, we also excluded observational studies with enrollment sizes of less than 250 unless no other studies were identified for a particular outcome; we also excluded studies that reported exposures only as servings of fish without calculating n-3 FA intakes, study size, exposure duration, or other similar criteria, if the number of studies identified is very large.

## Study Selection

The DistillerSR software package was used to manage the search outputs, screening, and data abstraction. Title/abstract screening was conducted in duplicate (after a training session to ensure understanding of the inclusion and exclusion criteria and reasonable inter-rater reliability), using a screening form that lists the inclusion and exclusion criteria and allows selection of reasons for exclusion. All title selections were accepted without reconciliation for further full-text review. Second-level screening of full text articles was conducted by two reviewers and differences reconciled (the project leaders settle disagreements, if needed).

Abstracts for a subset of ten percent of titles selected from the EMBASE search were reviewed; based on the acceptance rate of the abstracts, it was determined that no additional abstracts for publications identified in the EMBASE search would be screened for inclusion.

Reference lists of existing recent SRs on outcomes of interest were reviewed to ascertain that we did not miss relevant studies.

Studies that were excluded at the full-text screening stage are listed in Appendix B with the reasons for exclusion. Publications identified in the searches for this report that were included in the original report were excluded at this stage (for purposes of tracking the literature flow) and are listed in Appendix B, regardless of whether they were subsequently included in analyses in this report.

## Data Extraction

Accepted studies underwent single abstraction of study-level data and risk-of-bias assessment in Distiller, with audit by an experienced reviewer. Outcome data were abstracted by a biostatistician and audited by an experienced reviewer. We re-extracted data from studies included in the original report that were included in new pooled analyses as needed.

Data collection forms were designed by the project team in Distiller SR, piloted by the reviewers, further modified, and then the final forms piloted with a random selection of included studies to ensure agreement of interpretation. Studies based on large prospective cohorts were identified in their Distiller records to allow comparison to ensure data were not extracted in duplicate. Study-level data included PICOTs, baseline nutritional status/ biomarkers/other evidence of initial exposure to n-3 fatty acids as well as status of other nutrients that could influence outcomes (e.g., vitamin E), method of exposure assessment and associated margin of error, inclusion/exclusion criteria, study design, comorbidities, other potential effect modifiers, analytic methods, and characteristics necessary to assess risk of bias, including recruitment, blinding, allocation concealment, description of completeness of final dataset, funding source, and other potential conflicts of interest.

Outcome data, including clinical outcomes and intermediate outcomes (concentrations of biomarkers), were abstracted in duplicate in Excel files by the biostatistician and one additional reviewer. At the end of the project, abstracted data will be uploaded to the Systematic Review Data Repository (SRDR) for full public accessibility.

## Methodological Quality (Risk of Bias) Assessment of Individual Studies

We assessed the methodological quality of each study based on predefined criteria. Risk of bias among RCTs was assessed using the Cochrane Risk of Bias tool,^11^ which evaluates risk of selection bias, performance bias, detection bias, attrition bias, reporting bias, and other potential sources of bias. Risk of bias among observational studies was assessed using questions relevant for prospective studies from the Newcastle-Ottawa tools.^12^ Both tools were supplemented with nutrition-specific items in consultation with the TEP (e.g., those related to uncertainty of dietary assessment measurements and compliance).^13-15^ For pooled analyses with significant effect sizes, we assessed publication bias using the Egger's and Begg's tests. Studies that reported adverse events were also assessed for adverse event assessment and reporting using the McMaster Quality Assessment Scale of harms (McHarm).^16^ Any quality issues pertinent to specific outcomes within a study were noted and considered when determining the overall strength of evidence for conclusions related to those outcomes.

## Data Synthesis/Analysis

All included studies were summarized narratively and in summary tables that show the important features of the study populations, design, intervention/exposure, outcomes, and results; we built off and improved on the tables used in the original review. Separate summary tables were used to describe studies that report on a particular outcome of interest.

We analyzed the results of studies of different design separately, combining them if appropriate, and we compared and contrasted populations, exposures, and outcomes across study designs, examining any differences in outcomes between interventional and observational studies.

Statistical data were extracted from all trials with an outcome of interest. We considered meta-analyses when there were at least three trials with similar population (e.g., pregnant women, term infants, preterm infants), intervention (e.g., DHA, DHA+EPA, DHA+AA), follow-up time (e.g. birth, 12 months of age), and outcome measure. For trials that had groups with the same intervention but with varying doses, we averaged the outcome across doses for the main analysis. Forest plots were provided for random effects meta-analysis. We used the Hartung-Knapp-Sidik-Jonkman method for our random effects meta-analysis.(Hartung, 1999)^17^ (Hartung, 2001)^18^ (Sidik, 2006)^19^ It has been shown that the error rates from this method are more robust than the previously used DerSimonian and Laird method.^20^ Heterogeneity was assessed using the I2 statistic.^21^ All statistical analyses were performed in R 3.2.0.^22^

New trial results were added to original meta-analyses, when appropriate, based on similarity of participants, interventions (including doses), and outcomes.^9^ When sufficient data were available and clinical heterogeneity was minimal, we conducted dose-response meta-analysis (for observational studies) or meta-regression on doses (for RCTs) to support our qualitative synthesis. When new bodies of observational studies were added, possibility for random-effects multivariate dose-response meta-analysis was also assessed (Shekelle, 2014; Ahmadzai, 2013; Greenland, 1992; Orsini, 2012; Hamling, 2008).^23-27^ For meta-analysis of data with clear outliers, sensitivity analyses were conducted, if appropriate to the question.

## Summary of Causality-Related Study Features

Appendix I includes data related to possibility causality criteria for all included studies. The list of items in this table was compiled based on discussions between the EPCs and ODS after discussion of the Bradford Hill criteria and other issues related to determining causality.^8^ The table lists included studies with their timeframe, country, population category (pregnant, breastfeeding, preterm infant, term infant), baseline n-3 FA intake, n-3 FA source, n-3 FA type, how n-3 FA intake measured, study design (e.g., randomized controlled trial, prospective or retrospective longitudinal cohort, or other design), exposure duration, followup time, outcomes reported, effect sizes and types, difference in n-3 FA intake (between low and high intake groups), and whether outcomes were reported to be primary outcomes (vs. secondary or unspecified). The determination of primary outcomes was based on an explicit statement of the primary outcomes, the outcome used in reported power calculations, or implied by focus of the original article.

## Grading the Strength of Evidence (SOE) for Major Comparisons and Outcomes

The strength of evidence was assessed for each outcome and exposure type using the method outlined in the AHRQ Methods Guide^9^, in which the body of evidence for each outcome is assessed based on the following dimensions: study limitations (risk of bias), reporting bias, consistency (within and across study designs), and precision, as well as the number of studies by study design. Based on these assessments, we assigned a strength-of-evidence rating (i.e., insufficient, low, moderate, or high level of evidence). The data sources, basic study characteristics, and each strength-of-evidence dimensional rating were summarized in “Summary of Evidence Reviewed” tables detailing our reasoning for arriving at the overall strength of evidence rating (Appendix G). Applicability of studies to the populations and interventions that are the focus of the current review was assessed also, as described below.

## Assessing Applicability

The primary basis for assessment of applicability was the similarity of average intake of n-3 fatty acids (as fatty fish or other foods) to that of the U.S. and other healthy western populations at baseline. Studies of healthy pregnant women and healthy infants were also judged to have higher applicability than those enrolling women with a prior history of poor pregnancy outcomes or children with a family history of the conditions of interest. Studies in which the majority of participants were taking n-3 supplements at baseline were also rated as having lower applicability.

## Peer Review and Public Commentary

A draft version of this report was reviewed by a panel of expert reviewers, including representatives from the American Academy of Pediatrics and the American College of Obstetrics and Gynecology and the general public. The reviewers included experts in prenatal and postnatal development and in the clinical effects of n-3FA and representatives of dietary supplement trade organizations. These experts were either directly invited by the EPC or offered comments through a public review process. Revisions of the draft were made, where appropriate, based on their comments. The draft and final reports are also reviewed by AHRQ. However, the findings and conclusions are those of the authors, who are responsible for the contents of the report.