# Introduction

The omega-3 fatty acids (n-3 FA) (including alpha-linolenic acid [ALA], stearidonic acid [SDA], eicosapentaenoic acid [EPA], docosapentaenoic acid [DPA], and docosahexaenoic acid [DHA]) are a group of essential long-chain and very-long-chain polyunsaturated fatty acids (LC-PUFA) that are involved in the eicosanoid pathway and are incorporated into cell membranes. Eicosanoids (including prostaglandins, thromboxanes, and leukotrienes) have wide ranges of physiologic effects and play a key role in inflammation regulation. The metabolic pathway of n-3 FA is shown in Figure 1. ALA is the simplest n-3 FA, from which all other n-3 FA are metabolically derived. ALA must come from the diet, as it cannot be made by the body. ALA is found in plant foods, such as leafy green vegetables, nuts, and vegetable oils such as canola, soy, and flaxseed. SDA can be formed from ALA via Δ6-desaturase, the rate-limiting enzyme in the pathway. When SDA enters the metabolic pathway, it is rapidly converted to EPA. EPA can be converted to DPA and vice versa. The rates of conversion from ALA to EPA or DHA are highly variable. Good sources of EPA and DHA in the diet include fin fish, other seafood, other marine sources, and organ meats.

Figure 1 Metabolic pathway of omega-3 fatty acids

ALA = Alpha (α)-linolenic acid; DHA = Docosahexaenoic acid; DPA = Docosapentaenoic acid; EPA = Eicosapentaenoic acid; SDA = Stearidonic acid; n-3 = Omega-3 fatty acids

Figure 1 shows the metabolic pathway of n-3 fatty acids. The information displayed in the text above the figure describes the figure in more detail.

A role for n-3 FAs in prenatal and postnatal growth and development and risk for certain chronic diseases has been suggested by a variety of evidence from prospective cohort studies and randomized controlled trials (RCTs). In 2002, the Institute of Medicine (IOM) considered the evidence inadequate to establish an estimated average requirement (EAR) for n-3 FAs.^1^ Thus, in the absence of sufficient evidence, the IOM set only Adequate Intake values (AIs), based on current population intake in the apparent absence of deficiency symptoms.^a^ The IOM set the following AIs for n-3 FA (ALA, whose primary dietary sources are plant foods and algae) for healthy pregnant women and children:

- Pregnant women: 1.4 grams (g)/day (d) of ALA
- Infants (≤12 months): 0.5 g/d of n-3 FAs
- Children (1 to 3 years): 0.7g/d of ALA
- Children (4 to 8 years): 0.9 g/d of ALA

In 2004, at the request of the National Institutes of Health's (NIH) Office of Dietary Supplements (ODS), three Evidence-based Practice Centers (EPCs) conducted 11 systematic reviews (SRs) of the evidence for the health effects of n-3 FAs. Included among these SRs was one that encompassed outcomes related to the health of pregnant women and their children.^2^ Maternal outcomes included the risk for pregnancy hypertension and preeclampsia. Child health outcomes included risk for preterm birth, intrauterine growth retardation (IUGR) (small-for-gestational age and low birth weight); birth weight, length, and head circumference; neurological development; visual function in the first year of life; and various indices of cognitive development. This review found insufficient evidence to draw definitive conclusions about the effects of n-3 FA on maternal or child outcomes. Since the original review, many new studies and a number of SRs have examined the role of n -3 FAs in these outcomes. In addition, recent studies have suggested a potential role for n-3s in some related outcomes, e.g., the development of attention and working memory.^3^

## Scope and Key Questions

### Scope of the Review

The NIH ODS has a long history of commissioning AHRQ-based systematic reviews and research methodology reports for nutrient-related topics (http://ods.od.nih.gov/Research/Evidence-Based_Review_Program.aspx). The original 2005 systematic review^2^ did not reach strong scientific conclusions for many of the outcomes of interest, most likely related, at least in part, to the fact that some n-3 FA exposures were from fish and other marine sources, some were from dietary supplements, some were indirect (through breast milk), and many studies did not assess biomarkers. In addition, for outcomes of interest for which RCTs were available, observational studies were not considered, whereas for outcomes for which RCTs were unavailable or could not be conducted, the authors relied on observational studies of varying design. Studies of different designs each have their own strengths and weakness that may result in differences in conclusions. For example, observational studies based on self-reported dietary assessments (e.g., food frequency questionnaires) may inaccurately estimate n-3 FA intake; RCTs of specific fish or other n-3 FA-rich food may impose an artificial dietary pattern that might not be applicable to the general population; RCTs of supplements might not fully account for differences in background n-3 FA intake; studies using either study design may have subtle differences in eligibility criteria, e.g., length of follow-up period, or inclusion of ALA, EPA, and DHA or only EPA and DHA, that significantly impacted the final conclusions.

The current systematic review has four aims: 1) to update the original review on the topic of the effects of n-3 FAs on maternal and child outcomes(Lewin, 2005),^2^ 2) to identify the literature for several additional outcomes of interest (see below) not included in the original review; 3) to include prospective observational studies that were excluded from the original report when two or more RCTs were identified for an outcome of interest; and 4) to use this new review to collect additional information that would enhance the usefulness of this report for policy and clinical applications. Therefore, it is of interest to systematically compare results across different exposure/intervention products and study types (e.g., interventional vs. prospective cohort studies), and to account for differences in background n-3 FA intake.

This update includes the addition of seven new outcomes: (maternal) ante- and postnatal depression, and pediatric attention deficit hyperactivity disorder (ADHD), autism spectrum disorders (ASD), learning disabilities, atopic dermatitis, allergies, and respiratory disorders, specifically looking at the risk for (or prevention of) these conditions in otherwise healthy individuals and their offspring, rather than the efficacy of n-3 FA in treating affected individuals. The additional outcomes may present several challenges: a limited literature base; the need to rely largely, if not completely, on population-based cohort studies (RCTs are likely to be rare, and case-control studies are inadequate to address these issues); and the need to assess and distinguish the effects of potential maternal and postnatal exposures on postnatal outcomes. Furthermore, there are ongoing concerns in the scientific community regarding systematic biases and random errors in the determination of n-3 FA intakes from dietary and supplement sources, using currently available assessment tools. The limitations of the current methods have been discussed elsewhere.^4, 5^ To date, no alternate methods are available. Until “error-free” or “bias-free” methodologies are developed, it is crucial to evaluate the available data with the methodological quality and the limitations in mind. Nutrient biomarkers can provide an objective measure of dietary status. However, the correspondence between intake and biomarker concentration reflects not only recent intake but subsequent metabolism (e.g., elongation, desaturation, metabolism to bioactive compounds). Current biomarkers used to estimate n-3 polyunsaturated fatty acids intakes include ALA, EPA, SDA, and DHA, and are measured in adipose tissue, erythrocytes, plasma, or plasma phospholipids, placenta, and umbilical cord.^6, 7^ Adipose tissue FAs are thought to reflect long-term intake, erythrocytes FAs are thought to reflect the previous 120-day intake, and plasma FAs are thought to reflect more immediate intake.^7^

The 2005 review screened 2,049 abstracts, of which 117 articles (describing 89 studies) were included. Of the 89 studies, 63 were RCTs and 26 were observational studies. This current systematic review updated the outcomes included in the previous review and expanded the scope to include additional maternal (risk for perinatal depression) and childhood (risk for ADHD, autism, learning disabilities, allergy, and respiratory conditions) outcomes. Moreover, the current review systematically evaluated possible reasons for inconsistencies between observational and RCT findings by tabulating causality-related study features such as the Bradford Hill criteria.^8^

### Key Questions

The Key Questions address both issues of efficacy (i.e., causal relationships from trials) as well as associations (i.e., prospective cohort study results and outcomes or risk factors from RCTs for which the randomization may not be applicable). Compared with the Key Questions from the 2005 report, they expand the scope of the review to include additional maternal and child outcomes, as noted above and described below (shown in bold face).

Key Question 1: Maternal Exposures

– What is the efficacy of maternal interventions involving—or association of maternal exposures to—n-3 FA (EPA, DHA, EPA+DHA [long-chain n-3 FA], DPA, ALA, SDA or total n-3 FA) on the following:
  - duration of gestation in women with or without a history of preterm birth (less than 37 weeks gestation),
  - incidence of preeclampsia/eclampsia/gestational hypertension in women with or without a history of preeclampsia/eclampsia/gestational hypertension
  - Incidence of birth of small-for-gestational age human infants
  - Incidence of ante- and/or postnatal depression in women with or without a history of major depression or postpartum depression*
– What are the associations of maternal biomarkers of n-3 intake during pregnancy and the outcomes identified above?
– What are the effects of potential confounders or interacting factors (such as other nutrients or use of other supplements, or smoking status)?
– How is the efficacy or association of n-3 FA on the outcomes of interest affected by the ratio of different n-3 FAs, as components of dietary supplements or biomarkers?
– How does the ratio of n-6 FA to n-3 FA intakes or biomarker concentrations affect the efficacy or association of n-3 FA on the outcomes of interest?
– Is there a threshold or dose-response relationship between n-3 FA exposures and the outcomes of interest or adverse events?
– How does the duration of the intervention or exposure influence the effect of n-3 FA on the outcomes of interest?

Key Question 2: Fetal/childhood exposures

– What is the influence of maternal intakes of n-3 fatty acids or the n-3 fatty acid content of maternal breast milk (with or without knowledge of maternal intake of n-3 FA) or n-3 FA-supplemented infant formula or intakes of n-3 FA from sources other than maternal breast milk or supplemented infant formula on the following outcomes in term or preterm human infants?
  - Growth patterns
  - Neurological development
  - Visual function
  - Cognitive development
  - Autism
  - Learning disorders
  - ADHD
  - Atopic dermatitis
  - Allergies
  - Respiratory illness
– What are the associations of the n-3 FA content or the n-6/n-3 FA ratio of maternal or fetal or child biomarkers with each of the outcomes identified above?

Key Question 3: Maternal or childhood adverse events

– What are the short and long-term risks related to maternal intake of n-3s during pregnancy or breastfeeding on
  - Pregnant women
  - Breastfeeding women
  - Term or preterm human infants at or after birth
– What are the short and long-term risks associated with intakes of n-3s by human infants (as maternal breast milk or infant formula supplemented with n-3 FA)?
– Are adverse events associated with specific sources or doses?

## Analytic Frameworks

To guide the assessment of studies that examine the association between n-3 FA intake/exposure and the maternal and childhood outcomes of interest, we have created two analytic frameworks (Figures 2 and 3) that map the specific proposed linkages associating the populations of interest, the exposures, modifying factors, and outcomes of interest. The framework graphically presents the key components of the study questions presented above and further described in the Methods section, below.

1. Who are the participants (i.e., what is the population and setting of interest, including the diseases or conditions of interest)?
2. What are the interventions?
3. What are the outcomes of interest (intermediate and health outcomes)?
4. What study designs are of value?

Figure 2 Analytic framework for n-3 fatty acids in maternal health

Populations of interest, Exposure, Outcomes, and Effect modifiers are described. Solid connecting arrows indicate associations and effects reviewed in this report.

Note: This framework concerns the effect of n-3 FA exposure (as a supplement or from food sources) on maternal health outcomes. Populations of interest, Exposure, Outcomes, and Effect modifiers are described. Solid connecting arrows indicate associations and effects reviewed in this report.

ALA = alpha-linolenic acid, CAD = coronary artery disease, CHF = congestive heart failure, CKD = nondialysis-dependent chronic kidney disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, n-3 FA = omega-3 fatty acid(s); SDA = stearidonic acid.

Figure 2 depicts the PICOTS and potential effect modifiers for trials in which the mother is the focus of interventions or exposures (key question 1 and 3). Solid connecting arrows indicate associations and effects reviewed in this report. The top box describes participants (healthy mothers); the second box describes exposures and interventions of interest (omega-3 fatty acids), the third box describes biomarkers that indicate omega-3 fatty acid status; and the lowest box describes the maternal and neonatal outcomes associated with maternal exposures, including potential adverse effects (Key question 3). The text box to the right side describes some potential effect modifiers.

Figure 3 Analytic framework for n-3 fatty acids in child health

Populations of interest, Exposure Outcomes, Effect modifiers were listed. Solid connecting arrows indicate associations and effects reviewed in this report.

Note: This framework concerns the effect of n-3 FA exposure (as a supplement or from food sources) on infant health outcomes. Populations of interest, Exposure, Outcomes, and Effect modifiers are described. Solid connecting arrows indicate associations and effects reviewed in this report.

ALA = alpha-linolenic acid, CAD = coronary artery disease, CHF = congestive heart failure, CKD = nondialysis-dependent chronic kidney disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, SDA = stearidonic acid.

Figure 3 depicts the PICOTS and potential effect modifiers for trials in which the fetus, infant, or child is the focus of interventions or exposures (keys question 2 and 3). Solid connecting arrows indicate associations and effects reviewed in this report. The top box describes participants (fetuses, infants, toddlers, children to age 18); the second box describes exposures and interventions of interest (maternal breast milk, infant formula, or dietary supplemental omega-3 fatty acids), the third box describes biomarkers that indicate omega-3 fatty acid status; and the lowest box describes the childhood outcomes associated with these exposures. The text box to the right side describes some potential effect modifiers.

Specifically, this analytic framework depicts the chain of logic that evidence must support to link the intervention (exposure to n-3 FA) to improved health outcomes.

a The use of an AI instead of an EAR indicates the need for more research to determine, with confidence, the mean and distribution of requirements for that nutrient; AIs are based on much less data and more scientific judgment than are EARs.