# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Michael H. Bloch, M.S., M.D.
  Assistant Professor in the Child Study Center
  Yale University School of Medicine
  New Haven, CT
- Van S. Hubbard, M.D., Ph.D.
  Current:
  Rear Admiral, U.S. Public Health Service (Ret)
  At time of review:
  National Institutes of Health
  Director, Division of Nutrition Research Coordination
  Associate Director for Nutritional Sciences
  National Institute of Diabetes and Digestive and Kidney Diseases
  Washington, DC