# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Carlo Agostoni, M.D.^*^
  Professor of Pediatrics
  Department of Maternal and Pediatric Sciences
  University of Milan
  Fondazione IRCCS Ca' Granda – Ospedale Maggiore Policlinico
  Milan, Italy
- Jeanne A. Conry, M.D., Ph.D.^*^
  Assistant Physician in Chief
  North Valley Kaiser Permanente
  Roseville, CA
- Lisa Freund, Ph.D.^*^
  Chief, Child Development and Behavior Branch
  Eunice Kennedy Shriver National Institute of Child Health and Human Development
  Health and Human Development
  Bethesda, MD
- Peter Gillies, Ph.D.
  Founding Director of the New Jersey Institute for Food, Nutrition, and Health
  Rutgers University
  New Brunswick, NJ
- Ronald E. Kleinman, M.D.^*^
  Chair, Pediatrics Department, Mass General Hospital
  Physician-in-Chief, Mass General Hospital for Children
  Boston, MA
- Alice Lichtenstein, Sc.D.
  Stanley N. Gershoff Professor of Nutrition Science and Policy
  Tufts University Friedman School of Nutrition Science and Policy
  Director, Cardiovascular Nutrition Laboratory
  USDA Human Nutrition Research Center
  Boston, MA
- Maria Makrides, Ph.D.^*^
  Theme Leader, Healthy Mothers, Babies, and Children
  South Australian Health and Medical Research Institute
  Professor of Human Nutrition
  University of Adelaide
  North Adelaide, Australia
- John Paul SanGiovanni, Sc.D.
  Staff Scientist in the Clinical Trials Branch at the National Eye Institute
  National Institutes of Health
  Division of Epidemiology and Clinical Applications
  Bethesda, MD

* Provided input on Draft Report