# Discussion

## Overall Summary of Key Findings

For this systematic review, we identified 74 RCTs (in 75 publications) and 43 eligible prospective longitudinal studies and nested case-control studies that were eligible for inclusion based on the prespecified inclusion criteria. Most of the RCTs evaluated the effects of marine oil supplements on prenatal weight gain (risk for low birth weight) and length of gestation (risk for preterm birth) or the effects of DHA with or without AA as supplements or added to infant formulas on infant neural and cognitive development. Most observational studies assessed the association between the status of particular n-3 FA and developmental outcomes.

Within each category of analysis (by outcome, target of intervention, n-3 FA, and study design), studies diverged greatly with respect to the sources, doses, and durations of interventions; definitions or tests used to measure outcomes; and follow-up times. For outcomes such as visual, neurological, and cognitive development, by necessity, the tests used over time (in studies with multiple follow-ups) changed to match maturity level. As a result, it was challenging to identify groups of studies that were sufficiently similar to pool, even with studies from the original report. In addition, many RCTs employed and reported the results of numerous outcome measures, which were often internally inconsistent or showed no apparent pattern over time. The majority of studies did not find statistically significant findings. A small number of observational studies that were excluded from the original report met the inclusion criteria for the current report, and the observational studies identified for the current report seldom assessed outcomes that were similar to those assessed in RCTs. Additional challenges are described in the Limitations section below.

The original report found inconsistent effects of prenatal maternal supplementation with DHA on length of gestation and the risk for preterm birth and a consistent finding of no effects of prenatal maternal supplementation with EPA+DHA among a large number of RCTs. The current report found similar findings for these outcomes in RCTs.

For the current report, pooled analysis of 11 RCTs among healthy pregnant women found a significant increase in length of gestations among mothers who received algal DHA or DHA-enriched fish oil (WMD +0.34 [95% CI 0.02, 0.67] weeks) compared to placebo. Pooled analysis of 7 RCTs showed no significant effect of DHA or DHA-enriched fish oil on the incidence of preterm birth.

Pooled analysis of 5 RCTs showed that maternal fish oil supplementation (EPA+DHA) among healthy pregnant women had no significant effects on gestational age. Pooled analysis of 9 RCTs (in four publications) found no effects of EPA+DHA supplementation on the incidence of preterm birth. Prospective studies are sparse and found no consistent associations of maternal exposures with outcomes related to length of gestation or preterm birth.

The original report did not find a significant effect of maternal n-3 FA supplementation on the risk for low birth weight or SGA or a clear association of any maternal biomarkers with risk for low birth weight or birth weight itself. For the current report, we found a moderate level of evidence that maternal supplementation with DHA may increase birth weight, and a low level of evidence that maternal supplementation with EPA+DHA may not have significant effects on birth weight. Pooled analysis of 12 RCTs showed significantly higher birth weights among infants (mixed term and preterm) whose health pregnant women received algal DHA or DHA-enriched fish oil compared with placebo (WMD [95% CI]=90.12 [2.63, 177.62] grams). Pooled analysis of five RCTs found no effect of maternal EPA+DHA supplementation on infant birth weight. One RCT that assessed the effects of ALA on infant birth weight showed no effects. These findings are consistent with prospective studies, which found that higher maternal blood DHA concentrations were associated with higher birth weight.

There is also a low level of evidence that maternal supplementation with EPA+DHA may not have significant effects on risk for delivering a low birth weight infant among at-risk pregnant women, but the evidence is insufficient for the effects of maternal supplementation with DHA on risk for delivering a low birth weight infant among healthy pregnant women. Pooled analysis of four RCTs showed no significant effects of DHA+EPA supplementation (doses ranged from 2.0 to 3 g/d) on the incidence of small for gestational age between DHA+EPA supplementation and control groups (OR [95% CI]=1.00, CI[0.70, 1.43]). Two RCTs identified for the current study that assessed the effects of DHA alone or DHA-enriched fish oil both showed no significant effects on the risk for delivering a low birth weight infant among women who were not at risk. Observational studies were sparse and showed mostly no associations between n-3 intake or biomarkers and these outcomes.

The outcome of risk for antenatal and postnatal depression was a new one for this review. Three of the four RCTs that assessed the effects of prenatal supplementation with DHA alone, DHA+AA, or EPA-enriched fish oil or postnatal supplementation with DHA alone found no effects on risk for developing perinatal depression among healthy pregnant women. Prospective studies found inconsistent associations of maternal n3FA levels and risk of developing perinatal depression.

The original report found no consistent effect of maternal supplementation with n-3FA on the risk for gestational hypertension or preeclampsia. Pooling one study identified for the current report and two studies from the original report that randomized high-risk women to DHA supplements or placebo resulted in no difference in the risk for gestational hypertension or preeclampsia (OR 0.94[0.66, 1.34], I^2^=0% (n=2,818); pooling studies of women not at high risk wo were randomized to fish oil or placebo also showed no effect (OR 1.04 [0.76 , 1.42], I^2=^ 0%).

The original report found no, or inconsistent, effects of maternal supplementation or infant formula fortification on postnatal growth patterns. For the current report, pooled analysis of five RCTs of prenatal supplementation with DHA and EPA or fish oil showed no significant effects on weight, length, or head circumference at 18 months. Pooled analysis of three studies of fortification of infant formula with DHA and AA also showed no effects on postnatal weight and length at 4 months among preterm infants.

The original report found no consistent effect of maternal or infant supplementation with n-3 FA on neurological developmental outcomes and inconsistent associations with biomarkers. Likewise, RCTs identified for the current report found no consistent effects of n-3 FA alone or in combination with n-6 FA on any of these outcomes compared with placebo. Two studies reported a positive effect of formula supplemented with DHA and AA on Bayley's PDI scores (an index of motor development) in preterm infants at 12 and 18 months, and two RCTs reported positive effects on brainstem maturation but mixed effects on gross motor control in term infants supplemented with DHA and similarly mixed effects of DHA plus AA.

The original report found inconsistent effects of maternal and infant supplementation with n-3 FA on visual acuity development and inconsistencies between behavioral measures and electrophysiological measures (VEP). The current report identified one RCT that found that DHA supplementation of breast-feeding mothers resulted in improvement in one VEP outcome at 4 and 8 months of age but not at 5 years of age. We pooled five studies (four from the original report and one newly identified) that assessed the effects of supplementing infant formula with any n-3 FA on visual acuity development in preterm infants at 4 and 6 months and saw no significant effect of the intervention over that of placebo, although the effect approached borderline significance. Pooling studies (eight from the original report and two identified for the current report) of the effects of supplementing infant formula with any n-3 FA or with DHA plus AA on visual acuity among term infants showed small but significant effects at 2 months using behavioral methods, and at 4 and 12 months using VEP. Thus, results across time and outcome measure were inconsistent.

The original report found inconsistent effects of n-3 FA supplementation on cognitive development. We identified ten RCTs of pregnant women that reported cognitive outcomes in their offspring (including the only RCT identified in the prior systematic review); only two reported significant results. Six RCTs, including two from the previous AHRQ review, reported on supplementation for lactating women; none reported significant results. The prior AHRQ review included six RCTs in pre-term infants that reported cognitive outcomes, while the current one identified an additional six reports on five RCTs. Seven RCTs of pre-term infants reported the Bayley MDI score at 18 to 24 months of age; the pooled difference between the intervention and placebo groups was significant. The other RCTs reported mixed results. Two studies found no lasting differences during longterm (8 to 10 years) followup. Regarding healthy infants, the prior AHRQ review reported that six of eight RCTs did not find a significant difference between intervention and placebo groups in Bayley MDI scores. The current review identified five additional reports on four RCTs that measured cognitive outcomes. The pooled difference in MDI scores at 18 months was not significant when 3 RCTs were pooled. The RCTs that could not be pooled reported insignificant results regarding cognitive outcomes. Among six observational studies identified for the current report, only one association was noted: In one study that controlled for 18 potential confounders, low levels of AA were associated with lower performance IQ and high levels of adrenic acid were associated with lower verbal IQ at age 8; low levels of DHA were associated with lower verbal and full scale IQ, however, the authors caution that the effect sizes were small. In sum, there is moderate evidence that maternal n-3 supplementation has no effect on cognitive outcomes of offspring, while there is low strength evidence that supplementing formula for per-term infants may have a positive effect on cognitive outcomes at 18 months. However, there is insufficient evidence regarding long-term difference in cognitive outcomes. Developmental outcomes newly included for the current report were the risk for Autism Spectrum Disorders (ASD), Learning Disorders, and Attention Deficit Hyperactivity Disorder (ADHD). Two RCTs were identified that assessed the association between n-3 FA and the risk for ASD; one studied supplements for pregnant women and the other supplemented formula for pre-term infants. Both found no association with diagnosis of ASD. One large observational study on this topic was identified; women with the highest quartile of total PUFA intake while pregnant were at lower risk of having a child with ASD than women in the lowest quartile (RR 0.67; 95% CI 0.49, 0.92), after controlling for many important potential confounders. The authors advised that the results should be interpreted with caution, given the small number of cases (317 cases with ASD, 17,728 comparison mothers). Regarding ADHD, two RCTs of pre-term infants and one RCT of pregnant women measured attention or reported diagnoses of ADHD at long-term follow-up; each reported no association between supplementation and these outcomes.

Additional outcomes newly included in the current report were risks for atopic dermatitis/eczema, risks for allergies, and risks for respiratory illnesses, including asthma. A number of studies were conducted in mothers or infants at high familial risk for allergies or asthma. Three of four prenatal and three postnatal n-3 FA supplementation studies showed no significant effects on the risk for atopic dermatitis/eczema. Six of seven prospective observational studies also found no associations between n-3 FA exposures and risk for atopic dermatitis/eczema; however studies that assessed the association of n-3 FA biomarkers with this risk found inconsistent associations with higher plasma levels of DHA, erythrocyte EPA, AA levels, and EPA/AA ratios. Metaanalysis of three RCTs that assessed the effect of maternal supplementation with DHA plus EPA showed a reduction in the risk for food allergies that was not statistically significant. Prospective observational studies showed no consistent associations of maternal or infant n-3 FA exposures with risk for allergies. Among seven RCTs that assessed the effect of prenatal n-3 FA supplementation on the risk for respiratory illnesses, only two reported significant effects, decreases in the risk for asthma, but these effects were not consistent over time. A metaanalysis of three postnatal interventions that assessed the effects of fortified formula on risk for wheeze found no significant summary effect. Prospective observational studies and biomarker studies reported inconsistent associations between various postnatal n-3 FA and n-6 FA exposures and risk for respiratory illnesses.

The original report identified 21 RCTs that reported on adverse events with n-3 FA supplementation in pregnant women, breastfeeding mothers, and preterm and term infants. Overall they found that n-3 FA supplements and fortified formulas were well tolerated. Pregnant and breastfeeding women reported no serious adverse events, and adverse events in these groups were limited to mild GI symptoms. Among both preterm and term infants, adverse events were largely limited to GI symptoms also, with most serious adverse events attributable to morbidities associated with prematurity. The current report identified 18 RCTs that reported on adverse events. The profile of both non-serious and serious adverse events in this report was identical to that of the original report. None of the observational studies identified for the current report described adverse events.

Too few studies assessed the effects of increasing doses of n-3 FA using similar populations and outcome measures to enable dose-response or threshold estimation.

Few studies stratified outcomes according to risk groups, so it was usually not possible to assess whether the effectiveness of omega-3 interventions depended on level of risk. In addition, no studies stratified outcomes by baseline n-3 FA status, so it is not possible to assess whether adequacy of n-3 FA status might account for differences in outcomes across (or lack of outcomes within) studies.

## Limitations

Overall, both RCTs and observational studies included in this review had numerous quality concerns that could increase the risk for bias. Across RCTs, the most common risk-of-bias limitation was a lack of intention-to-treat analyses (54 percent of the included RCTs analyzed data per protocol). Of 95 included articles reporting on RCTs, 36 percent failed to describe allocation concealment sufficiently to determine whether it was adequate (and many studies failed to describe recruitment methods). Blinding of study participants contributed only slightly to potential risk of bias because participants were usually infants or children and outcomes were usually clinically apparent or assessed in a clinical laboratory. Thirty-seven percent of RCTs were at risk of attrition bias due to overall dropout rates greater than 20 percent, although most studies reported similar dropout rates between groups. Although 87 percent of the included RCTs reported similar baseline demographic characteristics between groups, 57 percent did not report baseline n-3 FA intake or status. This omission is a critical concern because baseline n-3 FA status likely affects response to changes in n-3 FA intake.

Across observational studies, the most common risk of bias limitation was the lack of representativeness of the cohorts to the population of interest: 35 percent were judged to be select populations or only somewhat representative. In most cases, these populations were described as having high intakes of fish; in several cases, the populations were at higher than average risk for the outcome of interest or another condition. Another reporting inadequacy related to the ranges and distribution of n-3 FA exposures: Of included observational studies, most of the n-3 FA dietary intake assessments included only dietary sources (not n-3 FA supplements).

Few studies reported adverse events, but among the 20 studies that did report adverse events, 60 percent did not predefine or prespecify adverse events to be queried, and none used a recognized categorization system to prespecify or sort categories or levels of intensity of adverse events reported. Only 35 percent reported an active mode of collection of adverse event information, and of the studies that reported serious adverse events (or lack thereof), most did not define “serious adverse event.” Of additional concern, studies of preterm infants often comingled morbidities associated with prematurity (such as bronchopulmonary dysplasia and retinopathy of prematurity) and adverse events that might be associated with the intervention. Only one study that met inclusion criteria considered whether mercury exposure could account for the findings on the effects of fish oil intake, but the findings were equivocal.

The population profiles differed somewhat between RCTs and observational studies. Understandably, a number of the RCTs were conducted in women at risk for premature birth, gestational hypertension, a low birth weight infant, or women with a personal or family history of allergy or asthma. However, most observational studies examining the associations between dietary n-3 FA intake or biomarkers of n-3 FA intake and birth, respiratory, allergy, or developmental outcomes were conducted in generally healthy populations. Most RCTs were also small in size, although most reported doing power calculations. Observational studies that enrolled fewer than 250 were excluded by design.

Study interventions or measured exposures tended to be highly heterogeneous. Studies that labeled themselves as studies of DHA alone often included some amount of EPA as well as n-6 FA (usually AA). Fish oil studies did not always report the oil's concentration of n-3 and n-6 FA in addition to the one of interest. Few studies assessed the effects of EPA alone and only one study assessed the effects of ALA alone. Of most concern was the heterogeneity in the description of the n-3 and n-6 FA contents of infant formulas and the systematic lack of assessment of formula intake (realizing the difficulty of this measurement in human infants). Few trials compared n-3 FA dose, formulation (e.g., ratio of EPA to DHA), or source. No trial compared different n-3 to n-6 FA ratios of supplements or intake. None of the observational studies attempted to determine a threshold effect of any associations between n-3 FA and the outcome of interest. Some observational studies failed to report median or range data of n-3 FA levels within quantiles, confidence intervals (or equivalent) of association hazard ratios, or conducted only linear analyses across a full range of n-3 FA values. In addition, studies varied in the range of n-3 FA status (e.g., intake level) within each study. The applicability of many of the observational studies to the U.S. population may also be limited by the higher baseline intakes of fish and other n-3 FA-containing foods and supplements among the populations in these studies.

Among studies that assessed associations between biomarkers of n-3 FA status and an outcome of interest, so many different n-3 FA biomarkers were investigated, that it was impossible to make comparisons across studies.

Another limitation of many of the studies was the inability or failure to control for potentially confounding factors. Observational studies often corrected for a large number of potential confounders, but many important factors could not be or were not measured; this issue is magnified for long-term follow up studies of cognitive development, where environmental factors were seldom considered. RCTs that reported cognitive outcomes at long-term follow up also rarely controlled for potential confounders, although they did report baseline data on characteristics such as SES and parent education, which were usually statistically similar among placebo and intervention groups.

For the outcomes related to infant and child development (except for growth patterns), tests used to measure most outcomes were numerous and heterogeneous across studies regardless of the study designs, and follow-up times varied widely. As a result, studies for a number of outcomes of interest could not be pooled, either with studies identified for the original report or with newly identified studies. In addition, the multiplicity of measures all but ensured that some outcome measure would produce a significant effect. Understandably, studies of cognitive, neurological, and visual acuity development with multiple follow-up points were required to use age/stage-appropriate outcome measures, but they seldom attempted to account for these changes in outcome measures.

The RCTs and observational studies differed in a number of ways, making it difficult to compare outcomes across the two study designs. Of note, the doses of n-3 FA supplements in RCTs were often much higher than the highest intake reported for observational studies. Furthermore, not all observational studies explicitly included n-3 FA supplements in their assessment of intake, and almost none of the RCTs attempted to account for background fish or n-3 FA intake as an effect modifier. For a very small number of RCTs where no significant differences in outcomes were observed between intervention and placebo treatments, posthoc analysis found an association between a biomarker of n-3 FA and the outcome of interest. This observation would seem to suggest that the apparent lack of effect of the intervention on the outcome of interest might be attributable to the participants having had adequate baseline n-3 FA status. However, the number of studies that conducted these follow-up analyses was too small to draw definitive conclusions. Likewise, very few RCTs assessed reported baseline dietary intakes of n-3 FA or biomarker status.

Finally, due to the significant heterogeneity across studies, the interpretation of overall meta-analysis results is limited. Only a small number of RCTs conducted dose response assessments (usually with poor results). For those reasons, we did not attempt to do dose-response meta-analysis of observational studies and performed only a small number of meta-regressions on dose-response across RCTs.

## Future Research Recommendations

Future RCTs should be designed to determine whether particular populations or individuals are more likely to benefit from n-3 FA supplements or fortified formulas, e.g., individuals with relatively low baseline intakes of n-3 FA.

Therefore, studies need to measure—and match intervention groups according to—baseline n-3 FA biomarker status (although the current report has not clearly revealed the most relevant biomarkers). Researchers need to reach consensus on standardized formulations and on reporting of concentrations for interventions. The results of this review should help guide these decisions.

Studies also need to ascertain whether n-3 FA are more effective in individuals at increased risk for particular conditions (such as low birth weight, preterm birth, gestational hypertension, or for infants, risk for delayed visual acuity development or atopy).

Some recent evidence suggests that individuals' abilities to benefit from dietary supplementation with n-3 FA (or breastfeeding) is influenced by polymorphisms within the gene encoding FADs2, an enzyme involved in the desaturation of fatty acids to convert precursors to LCPUFAs such as DHA. If these findings are confirmed, future studies may need to perform genetic profiles on potential participants and to exclude those who are genetically incapable of responding to supplementation.

Finally, identifying the most promising and clinically relevant outcome measures will be important to expanding the strength of the evidence base for the effectiveness of supplemental n-3 FA for maternal and childhood outcomes. The findings of large cohort studies are still needed to assess the potential role of n-3 FA status in the risk for conditions such as autism spectrum disorder, learning disabilities, and ADHD; however, it may be necessary first to identify clear intermediate risk factors for these conditions, because the length of follow-up needed for diagnosis of the conditions themselves greatly increases the potential interference of other confounding factors.

## Conclusions

### Maternal Exposures and Birth Outcomes

Strength of evidence (SoE) is low for a small positive effect of algal docosahexaenoic acid (DHA) or DHA-enriched fish oil on length of gestation compared with placebo; strength of evidence is low regarding an apparent lack of effect of DHA or DHA-rich fish oil on risk for preterm birth. Strength of evidence is insufficient to draw conclusions about effects or associations for other n-3 FA alone or in combination. Observational studies did not show consistent associations of n-3 FA exposures (intake measurements or biomarkers) with these outcomes.

SoE is also moderate for a positive effect of algal DHA or DHA-enriched fish oil on birth weight but strength of evidence is insufficient to draw conclusions for the effects of most n-3 FA interventions on low birth weight or small-for-gestational age (SGA) infants; maternal n-3 FA biomarkers were significantly associated with birth weight, and low SoE supports an association of low early pregnancy plasma EPA and risk for SGA.

A low SoE supports a lack of effect of DHA or DHA-rich fish oil on (or association of n-3 FA with) risk for gestational hypertension SoE is insufficient to draw conclusions about the effects of other n-3 FA interventions, either pre- or postnatal.

A moderate SoE supports a lack of effect of DHA supplementation on the risk for gestational hypertension or preeclampsia among high-risk pregnant women. SoE is insufficient to draw conclusions regarding the effects of other interventions.

### Infant and Child Outcomes

A moderate SoE supports a lack of effect of prenatal maternal supplementation with fish oil or DHA plus EPA on postnatal growth patterns (attainment of weight, length, and head circumference); a low SoE supports a lack of effect of pre- and postpartum maternal supplementation on these outcomes. SoE is insufficient to draw conclusions about the effects of other pre- or postnatal maternal interventions. A low SoE supports a lack of effect of DHA plus AA-fortified infant formulas on growth patterns of preterm or term infants. SoE is insufficient regarding effects of other n-3 FA or supplementation at other times on growth patterns.

A moderate SoE supports a lack of consistent effect of prenatal DHA on development of visual acuity in infants. SoE is insufficient to draw conclusions regarding the effects of other n-3 FA supplementation of pregnant or breastfeeding women on visual acuity. A low SoE supports a lack of effect of supplementation of infant formula with any n-3 FA on visua acuity measured in preterm infants at 4 or 6 months corrected age. A moderate SoE supports an effect of supplementation of infant formula with any n-3 FA on VEP-measured visual acuity development in term infants at 4 and 12 months of age but not on visual acuity measured using behavioral methods. A low SoE supports a small positive effect of supplementation of term infant formula with DHA plus AA on VEP but not on visual acuity measured using behavioral methods in term infants at 4 and 12 months.

A low SoE supports inconsistent effects of prenatal DHA on any measure of neurological development; insufficient SoE supports conclusions regarding the effects of any other n-3 FA supplementation of pregnant or breastfeeding mothers, or supplementation of preterm or term infants on measures of neurological development or associations of prenatal n-3 FA biomarker status and n-3 FA intakes with infant neurological development.

Regarding cognitive developmental outcomes, a moderate SoE supports a lack of effect of supplementation of pregnant women with either DHA plus AA or DHA plus EPA on cognitive outcomes in offspring. A low SoE supports lack of consistent effect of n-3 supplementation for full term infants on cognitive outcomes; there is moderate SoE that supplementing pre-term infants' formula with DHA plus AA may have a positive effect on infant cognition. There is insufficient evidence that any n-3 infant supplements are associated with long-term cognitive outcomes.

A low SoE supports the conclusion that n-3 FA status is unrelated to risk for autism spectrum disorders or ADHD.

A low SoE supports inconsistent effects of prenatal or postnatal n-3 FA supplementation on the risk for atopic dermatitis/eczema and allergies and associations of biomarkers and intakes with these outcomes. A moderate SoE supports a lack of effect of prenatal and postnatal infant n-3 FA supplementation on the risk for asthma and other respiratory illnesses. A low level of evidence supports inconsistent associations between n-3 FA exposures and risk for respiratory illnesses.

Table 29 summarizes the findings for which we identified a low, moderate, or high strength of evidence (SoE) for an effect or no effect of n-3 FA.

Table 29 Conclusions with strength of evidence for an effect or lack of effect

Outcome | Intervention/Exposure | Study Design^a^ | Strength of Evidence^b^ | Conclusion^c^
Maternal outcomes
Length of gestation | Healthy pregnant women: n-3 FA*^d^ supplementation | 12 RCTs 4 observational studies | Moderate | RCTs: Increase in gestational length compared with placebo Meta-analysis of 12 RCTs in update: WMD 0.33 (95% CI 0.04, 0.62) weeks. Observational studies: No associations. Original report: mixed findings .
Length of gestation | Healthy pregnant women: Algal DHA or DHA-enriched fish oil supplementation | 11 RCTs 4 observational studies | Moderate | RCTs: Increase in gestational length compared with placebo Meta-analysis of 11 RCTs in update: WMD 0.34 (95% CI 0.02, 0.67) weeks Observational studies: No associations. Original report: mixed findings
Length of gestation | Healthy pregnant women: EPA+DHA fish oil supplementation | 7 RCTs 4 observational studies | Low | RCTs: No significant effects on gestational length compared with placebo Observational studies: 3 of 4 found no association. Original report: no effects found^e^
Risk for preterm birth | Healthy pregnant women: Algal DHA or DHA-enriched fish oil supplementation | 7 RCTs | Low | RCTs: No significant effects on the incidence of preterm birth compared with placebo Meta-analysis of 7 RCTs: OR 0.87 (95% CI 0.66, 1.15)
Risk for preterm birth | At-risk pregnant women: EPA+DHA fish oil supplementation | 9 RCTs 2 observational studies | Low | RCTs:No significant effects on the incidence of preterm birth compared with placebo Meta-analysis of 9 RCTs: 0.86 (95% CI 0.65, 1.15) Observational studies showed mixed results.
Birth weight | Healthy pregnant women: n-3 FA* supplementation | 16 RCTs 10 observational studies | Moderate | RCTs: Significant Increase in birth weight compared with placebo Meta-analysis of 16 RCTs in update: WMD 74.8 (95% CI 12.4, 137.17) grams. Observational studies of dietary intake, supplement use, and biomarkers generally showed positive associations with birth weight. Original report: Mixed findings
Birth weight | Healthy pregnant women: Algal DHA or DHA-enriched fish oil supplementation | 12 RCTs 3 observational studies | Moderate | RCTs: Significant Increase in birth weight compared with placebo Meta-analysis of 12 RCTs: WMD 90.12 (95% CI 2.62, 177.62) grams Observational studies showed associations between DHA intake and biomarkers and birth weight. Original report: mixed findings
Birth weight | Healthy pregnant women: EPA+DHA fish oil supplementation | 5 RCTs 4 observational studies | Low | RCTs: No significant effects on birth weight compared with placebo Meta-analysis of 5 RCTs: WMD 37.89 (95% CI -19.53, 95.31) grams Observational studies showed mixed associations with birth weight. Original report: no effects
Low birth weight | Healthy pregnant women: Algal DHA or DHA-enriched fish oil supplementation | 4 RCTs | Low | RCTs: No significant effects on risk of low birth weight compared with placebo Meta-analysis of 4 RCTs: OR 0.72 (95% CI 0.43, 1.11)
SGA / IUGR | At-risk pregnant women: EPA+DHA or fish oil supplementation | 4 RCTs 2 observational studies | Low | RCTs: No significant effects on SGA/IUGR compared with placebo Observational studies: no consistent association with SGA Meta-analysis of 4 RCTs: OR 1.00 (95% CI 0.70, 1.43)
Gestational hypertension | Normal-risk pregnant women: DHA supplementation | 3 RCTs | Low | RCTs: No significant effect on risk for gestational hypertension in normal risk women Meta-analysis of 3 RCTs OR 0.94 (95% CI 0.66, 1.34)
Gestational hypertension | High-risk pregnant women: Marine oil supplementation | 3 RCTs | Moderate | RCTs: No significant effect on risk for gestational hypertension among high-risk women Meta-analysis of 3 RCTs OR 1.04 (95% CI 0.76 , 1.42)
Peripartum depression | Pregnant women: Prenatal DHA, DHA-rich fish oil, DHA+AA, EPA+DHA/fish oil, or any n-3 FA | 4 RCTs 8 observational studies | Low | RCTs: Nosignificant effect on risk for peripartum depression across studies. Observational studies showed no associations with risk for depression.^e^
Infant and child outcomes
Postnatal growth patterns | Pregnant women: Fish oil or DHA+EPA supplementation | 7 RCTs 2 observational studies | Moderate | RCTs: No significant effect on postnatal growth patterns among healthy term infants. Observational studies: Consistent with RCTs^e^
Postnatal growth patterns | Breastfeeding women: Supplementation with any n-3FA | 6 RCTs 1 observational study | Low | RCTs: No- significant effect on postnatal growth patterns Observational study: consistent with RCTs^e^
Postnatal growth patterns | Preterm or term infants: Feeding infant formula fortified with DHA+AA | 47 RCTs | Low | RCTs: No significant effect on postnatal growth patterns^e^
Visual acuity | Pregnant women: Supplementation with DHA-enriched fish oil | 4 RCTs | Low | RCTs: No significant effect on development of visual acuity in infants.^e^
Visual acuity | Preterm infants: Feeding infant formula supplemented with any n-3 FA | 5 RCTs | Low | VEP RCTs: No significant effect in preterm infants 4 months corrected age WMD -0.06 (−0.12; 0.01)
Visual acuity | Preterm infants: Feeding infant formula supplemented with any n-3 FA | 5 RCTs | Low | VEP RCTs: No significant effect on development of visual acuity in preterm infants 6 months corrected age WMD -0.04 (-0.09, 0.01)
Visual acuity | Term infants: Feeding infant formula supplemented with any n-3 FA | 6 RCTs | Low | Behavioral measures RCTs: Significant effect at 2 months WMD 0.07 (0.00, 0.14) six RCTs
Visual acuity | Term infants: Feeding infant formula supplemented with any n-3 FA | 6 RCTs | Low | VEP RCTs: No significant effect at 2 months WMD 0.07[-0.03, 0.17], six RCTs
Visual acuity | Term infants: Feeding infant formula supplemented with any n-3 FA | 6 RCTs | Low | Behavioral measures RCTs: No significant effect at 4 months WMD -0.05 (-0.08, 0.01) six RCTs
Visual acuity | Term infants: Feeding infant formula supplemented with any n-3 FA | 6 RCTs | Moderate | VEP RCTs: Significant effect at 4 months WMD -0.10(-0.14, -0.07), six RCTs
Visual acuity | Term infants: Feeding infant formula supplemented with any n-3 FA | 8 RCTs | Low | Behavioral measures RCTs:No significant effect of n-3 FA at 12 months WMD -0.10 (-0.14, -0.07)
Visual acuity | Term infants: Feeding infant formula supplemented with any n-3 FA | 8 RCTs | Moderate | VEP RCTs: Significant effect of n-3 FA at 12 months WMD -0.14 (-0.17, -0.12)
Visual acuity | Term infants: Feeding DHA plus AA-fortified infant formula | 7 RCTs | Low | VEP RCTs: Significant effect of DHA+AAat 4 months. WMD -0.10 (-0.14, -0.07)
Visual acuity | Term infants: Feeding DHA plus AA-fortified infant formula | 6 RCTs | Moderate | VEP RCTs: Significant effect of DHA+AA at 12 months WMD -0.14 (-0.17, -0.12)
Neurological development | Pregnant women: Supplementation with any n-3 FA | 17 RCTs 5 observational studies | Low | RCTs: No significant effects on measures of neurological development across studies (insufficient numbers of studies of any outcomes to pool) consistent with observational studies.^e^
Cognitive development | Pregnant women: Supplementation with DHA+EPA or DHA + AA | 10 RCTs | Moderate | RCTs: No significant effects on cognitive development across studies^e^
Cognitive development | Preterm infants: Supplementation with any n-3 FA | 11 RCTs | Moderate | RCTs: Significant increase in cognitive (MDI) scores WMD 2.24; (95% CI 0.05, 4.43)
Cognitive development | Term infants: Supplementation with DHA+ AA | 12 RCTs | Low | RCTs: No significant effect on cognitive development at 18-24 months WMD 0.75, 95% CI -9.29, 10.79
Autism Spectrum Disorders (ASD) | Pregnant women or preterm infants: Supplementation with DHA | 2 RCTs 1 observational study | Low | RCTs: No significant effect on risk for ASD; association shown for intake of n-3 FA in observational study^e^
ADHD | Pregnant women or preterm infants: Supplementation with DHA | 3 RCTs | Low | RCTs: No significant effect on risk for ADHD^e^
Atopic dermatitis/ eczema | Pregnant women: Supplementation with any n-3 FA or exposures as assessed by biomarkers | 4 RCTs | Low | RCTs: No significant (and inconsistent) effects on risk for atopic dermatitis/eczema
Atopic dermatitis/ eczema | Breastfeeding women or infants: Supplementation of mothers or infants through formula fortification with any n-3 FA or exposure as assessed with biomarkers | 3 RCTs 7 observational studies | Low | RCTs: No significant (and inconsistent) effects on risk for atopic dermatitis/eczema across RCTs, consistent with observational studies^e^
Allergies | Pregnant women: Supplementation with any n-3 FA or exposures as assessed by biomarkers | 3 RCTs 4 observational studies (including 3 biomarker studies) | Low | RCTs: No significant effect on the risk for food allergy at 12 months OR 0.54 (95% CI 0.05, 6.2); Observational studies: no consistent association of biomarkers and risk for allergy
Allergies | Breastfeeding women or infants: Supplementation of mothers or infants through formula fortification with any n-3 FA or exposure as assessed by biomarkers | 3 RCTs 2 observational studies | Low | RCTs: No significant effect on the risk for food or dust mite allergy and no association of breastmilk or infant biomarkers and risk for allergies across observational studies^e^
Asthma and other respiratory illnesses | Pregnant women: Supplementation with any n-3 FA | 6 RCTs | Moderate | RCTs: No significant effect on the risk for asthma and other respiratory illnesses Meta-analysis of 3 RCTs OR 0.95 95% CI 0.77, 1.16
Asthma and other respiratory illnesses | Breastfeeding women or infants: Supplementation of mothers or infants through formula fortification with any n-3 FA | 3 RCTs | Moderate | RCTs: No significant effect on the risk for asthma and other respiratory illnesses^e^
Asthma and other respiratory illnesses | Pregnant women or infants: Any n-3 FA exposures | 10 observational studies | Low | Observational Studies: Inconsistent associations with risk for respiratory illnesses across studies. ^e^
Asthma and other respiratory illnesses: Wheeze | Breastfeeding women or infants: Supplementation of mothers or infants through formula fortification with DHA | 3 RCTs 5 observational studies 4 biomarkers studies | Low | RCTs: No significant effect on risk for wheeze at 12 months; meta-analysis of 3 RCTs: OR 1.06 (95% CI 0.73,1.54) Observational studies: showed Inconsistent associations with risk for wheeze across studies
Adverse events
Maternal adverse events Non-serious | Pregnant or breastfeeding women: Supplementation with n-3 FA in the form of fish oil | 9 RCTs | Moderate | RCTs: Increased risk for mild gastrointestinal symptoms but no other consistent non-serious adverse events. ^e^
Maternal adverse events serious | Pregnant or breastfeeding women: Supplementation with n-3 FA in the form of fish oil | 4 RCTs | Moderate | RCTs: No significant difference in risk for serious adverse events.^e^
Infant adverse events non-serious | Healthy term infants or preterm infants: Supplementation with n-3 FA in the form of fish oil alone or added to infant formula | 13 RCTs | Moderate | RCTs:Increased risk for mild gastrointestinal symptoms across studies but no other consistent non-serious adverse events.^e^
Infant adverse events serious | Healthy term infants: Supplementation with n-3 FA in the form of fish oil | 6 RCTs | Moderate | RCTs:No significant difference in risk for serious adverse events.^e^
Infant adverse events serious | Preterm infants: Supplementation with n-3 FA in the form of fish oil | RCTs | Low | RCTs:No significant difference in risk for serious events associated with preterm birth.^e^

AA = arachidonic acid; ALA = alpha linolenic acid; CI = confidence interval; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; IUGR = intrauterine growth retardation; n-3 FA = omega-3 fatty acid; OR odds ratio; RCT = randomized controlled trial; SGA = small for gestational age; VEP = visual evoked potentials; WMD = weighted mean difference

a Figures represent numbers of studies considered as evidence in drawing the conclusion;

b Strength of evidence (SoE) was assessed using a modification of the GRADE method; the assessments for each domain considered in assigning the overall SoE grade are provided in Appendix G for each outcome; RCT outcomes were compared with observational study outcomes, when available, to contribute to the “consistency” domain;

c Meta-analysis results are shown for all outcomes for which studies were pooled; remaining conclusions are based on trends across studies;

d Any n-3 FA refers to a pooled analysis of studies that employed any or unspecified n-3 FA;

e RCTs determined to be too heterogeneous to permit pooling.

### Adverse Events

A moderate SoE supports a lack of serious adverse events (AEs) among pregnant women and infants who consume supplemental n-3 FA or foods fortified with n-3 FA; a moderate SoE supports a lack of non-serious AEs, with the exception of an increased risk for mild gastrointestinal symptoms, among pregnant women and infants who consume supplemental n-3 FA.

## Overall Conclusions

Most studies identified for this report examined the effects of marine oil (or other combinations of DHA and EPA) supplements on pregnant or breastfeeding women or the effects of infant formula fortified with DHA plus arachidonic acid. With the exception of small effects on birth weight and length of gestation (confirming the findings of the original report), n-3 FA supplementation or fortification has no consistent evidence of effects on peripartum maternal or infant health outcomes. No effects of n-3 FA were seen on gestational hypertension, peripartum depression, or postnatal growth. Apparent effects of n-3 FA supplementation were inconsistent across assessment methods and followup times for outcomes related to infant visual acuity and cognitive development and prevention of allergy and asthma. Evidence was insufficient to draw conclusions regarding effects of n-3 FA on or associations of n-3 FA exposures with autism spectrum disorders, ADHD, and learning disabilities. Future RCTs need to assess standardized preparations of n-3 and n-6 FA, using a select group of clinically important outcomes, on populations with baseline n-3 FA intakes typical of those of most western populations.