# Appendix I Causality Table

CAUSALITY TABLE

Study | Study years (start date) | Country | Population | (total) | intake | (Baseline) | n-3 type(s) | study_design | Follow-up time | Outcome | Effect size type (OR or SMD) | Reported effect Size | Outcome classification
Miles, 2011 | NR | UK | Healthy pregnant women | 107 | | | Salmon vs Control | Trial randomized parallel | birth | birth weight | SMD | 0.042469915 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 27 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 12 months (corrected age) | head circumference | SMD | 0 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 28 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 12 months (corrected age) | head circumference | SMD | -0.133630619 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 35 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 35 weeks (corrected age) | head circumference | SMD | -0.128260076 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 36 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 35 weeks (corrected age) | head circumference | SMD | -0.372677982 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 28 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 4 months (corrected age) | head circumference | SMD | 0.075592898 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 30 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 4 months (corrected age) | head circumference | SMD | -0.393858671 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 36 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 40 weeks (corrected age) | head circumference | SMD | 5.202124119 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 35 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 40 weeks (corrected age) | head circumference | SMD | 7.646153927 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 27 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 12 months (corrected age) | length | SMD | 0.763140142 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 28 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 12 months (corrected age) | length | SMD | 0.386043996 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 36 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 35 weeks (corrected age) | length | SMD | 0.094280906 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 35 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 35 weeks (corrected age) | length | SMD | 0.079324059 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 28 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 4 months (corrected age) | length | SMD | 0.381801784 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 30 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 4 months (corrected age) | length | SMD | -0.359404892 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 35 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 40 weeks (corrected age) | length | SMD | 0.038912445 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 36 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 40 weeks (corrected age) | length | SMD | 0.067343503 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 27 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 12 months (corrected age) | weight | SMD | 0.157750756 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 28 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 12 months (corrected age) | weight | SMD | -0.325969994 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 36 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 35 weeks (corrected age) | weight | SMD | -0.124950208 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 35 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 35 weeks (corrected age) | weight | SMD | -0.111058012 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 28 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 4 months (corrected age) | weight | SMD | -0.112528399 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 30 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 4 months (corrected age) | weight | SMD | -0.083675906 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 36 | | | DHA+ARA (FF) vs Control | Trial randomized parallel | 40 weeks (corrected age) | weight | SMD | -0.220495641 | Secondary
Groh-Wargo, 2005 | sept 1997 - Sept 1998 | US | Preterm infants | 35 | | | DHA+ARA (EF) vs Control | Trial randomized parallel | 40 weeks (corrected age) | weight | SMD | -0.282478869 | Secondary
Sala-Vila, 2004 | nr | Spain | Healthy infants | 23 | | | (HM) | Trial randomized parallel | 3 months | head circumference | SMD | 0.027388405 | Unspecified
Sala-Vila, 2004 | nr | Spain | Healthy infants | 23 | | | Milk (HM) | Trial randomized parallel | 3 months | head circumference | SMD | 0.396647155 | Unspecified
Sala-Vila, 2004 | nr | Spain | Healthy infants | 23 | | | Milk (HM) | Trial randomized parallel | 3 months | length | SMD | 0.027344823 | Unspecified
Sala-Vila, 2004 | nr | Spain | Healthy infants | 23 | | | (HM) | Trial randomized parallel | 3 months | length | SMD | 0.029529136 | Unspecified
Sala-Vila, 2004 | nr | Spain | Healthy infants | 23 | | | (HM) | Trial randomized parallel | 3 months | weight | SMD | 0.076811403 | Unspecified
Sala-Vila, 2004 | nr | Spain | Healthy infants | 23 | | | Milk (HM) | Trial randomized parallel | 3 months | weight | SMD | 0.011815406 | Unspecified
Hoffman, 2008 | nr | US | Healthy infants | 179 | | | DHA + ARA vs Control | Trial randomized parallel | 14-120d | head circumference | SMD | 0 | Secondary
Hoffman, 2008 | nr | US | Healthy infants | 179 | | | DHA + ARA vs Control | Trial randomized parallel | 14-120d | length | SMD | 0 | Secondary
Hoffman, 2008 | nr | US | Healthy infants | 179 | | | DHA + ARA vs Control | Trial randomized parallel | 14-120d | weight | SMD | -0.07062757 | Secondary
Doornbos, 2009 | Not reported | Netherlands | Healthy pregnant women | | | 4.44 (3.00–6.92); | group | Trial randomized parallel | 36 weeks pregnant | Depression Scale (EPDS) | | NC | Secondary
Doornbos, 2009 | Not reported | Netherlands | Healthy pregnant women | | | 4.44 (3.00–6.92); | DHA group vs Control group | Trial randomized parallel | 36 weeks pregnant | Depression Scale (EPDS) | | NC | Secondary
Doornbos, 2009 | Not reported | Netherlands | Healthy pregnant women | | | 4.44 (3.00–6.92); | group | Trial randomized parallel | 6 weeks post-partum | Depression Scale (EPDS) | | NC | Secondary
Doornbos, 2009 | Not reported | Netherlands | Healthy pregnant women | | | 4.44 (3.00–6.92); | DHA group vs Control group | Trial randomized parallel | 6 weeks post-partum | Depression Scale (EPDS) | | NC | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 12 weeks | definitely abnormal | OR | 0.387387395 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 12 weeks | definitely abnormal | OR | NC | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 2 weeks | definitely abnormal | OR | 3.405405521 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 2 weeks | definitely abnormal | OR | 3.486486435 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 12 weeks | mildly abnormal | OR | 0.513333321 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 12 weeks | mildly abnormal | OR | 0.894841254 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 2 weeks | mildly abnormal | OR | 0.83518517 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 2 weeks | mildly abnormal | OR | 0.641666651 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 12 weeks | normal optimal | OR | 0.439024389 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 12 weeks | normal optimal | OR | 0.172093019 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 2 weeks | normal optimal | OR | 0.286821693 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 2 weeks | normal optimal | OR | 0.878048778 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 12 weeks | normal suboptimal | OR | 0.596273303 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 12 weeks | normal suboptimal | OR | 0.992576897 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 2 weeks | normal suboptimal | OR | 0.766917288 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 2 weeks | normal suboptimal | OR | 1.016688108 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 2 weeks | classification: number | OR | NC | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 2 weeks | classification: number | OR | NC | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 2 weeks | classification: number mildly | OR | 1.361111164 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 2 weeks | classification: number mildly | OR | 0.996527791 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | 2 weeks | classification: number normal | OR | 1.034843206 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | 2 weeks | classification: number normal | OR | 1.071428537 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 78 | | | DHA group vs placebo | Trial randomized parallel | birth | gestational age birth | SMD | 0 | Secondary
van Goor, 2010 | until December 2006 | Netherlands | Breast-feeding women | 77 | | | DHA + AA group vs placebo | Trial randomized parallel | birth | gestational age birth | SMD | 0 | Secondary
Tofail, 2006 | enrollment January to March 2000 | Bangladesh | pregnant women | 249 | | | DHA supplement vs placebo | Trial randomized parallel | birth | birth weight | SMD | 0 | Unspecified
Tofail, 2006 | enrollment January to March 2000 | Bangladesh | pregnant women | 249 | | | DHA supplement vs placebo | Trial randomized parallel | 10 months | Development (Mental | SMD | 0.12656565 | Unspecified
Tofail, 2006 | enrollment January to March 2000 | Bangladesh | pregnant women | | | | | Trial randomized parallel | | Development (Psychomotor | | | Unspecified
Tofail, 2006 | enrollment January to March 2000 | Bangladesh | pregnant women | 249 | | | DHA supplement vs placebo | Trial randomized parallel | 10 months | Development (Psychomotor | SMD | 0.114185289 | Unspecified
Tofail, 2006 | enrollment January to March 2000 | Bangladesh | pregnant women | 249 | | | DHA supplement vs placebo | Trial randomized parallel | 10 months | head circumference | SMD | -0.142857149 | Unspecified
Peat, 2004 | 2000-2003 | Australia | unborn children were at | 526 | | | Placebo group | design | 3 years | any eczema | OR | 1.226132035 | Secondary
Peat, 2004 | 2000-2003 | Australia | unborn children were at | 526 | | | Placebo group | design | 3 years | any asthma | OR | 1.040522456 | Primary
Peat, 2004 | 2000-2003 | Australia | unborn children were at | 526 | | | Placebo group | design | 3 years | any cough | OR | 1.226132035 | Primary
Peat, 2004 | 2000-2003 | Australia | unborn children were at | 526 | | | Placebo group | design | 3 years | any wheeze | OR | 1.040522456 | Secondary
Birch, 2007 | 1993-1999 | US | women whose unborn | 35 | | | DHA vs Control | Trial randomized parallel | 4 years | Primary Scale of Intelligence: | SMD | 0.36454019 | Secondary
Birch, 2007 | 1993-1999 | US | women whose unborn | 51 | | | DHA+ARA vs Control | Trial randomized parallel | 4 years | Primary Scale of Intelligence: | SMD | 0.418064356 | Secondary
Birch, 2007 | 1993-1999 | US | women whose unborn | 35 | | | DHA vs Control | Trial randomized parallel | 4 years | Primary Scale of Intelligence: | SMD | 0.290230393 | Secondary
Birch, 2007 | 1993-1999 | US | women whose unborn | 51 | | | DHA+ARA vs Control | Trial randomized parallel | 4 years | Primary Scale of Intelligence: | SMD | 0.267109424 | Secondary
Birch, 2007 | 1993-1999 | US | women whose unborn | 51 | | | DHA+ARA vs Control | Trial randomized parallel | 4 years | Primary Scale of Intelligence: | SMD | 0.386548072 | Secondary
Birch, 2007 | 1993-1999 | US | women whose unborn | 35 | | | DHA vs Control | Trial randomized parallel | 4 years | Primary Scale of Intelligence: | SMD | 0.281229317 | Secondary
Birch, 2007 | 1993-1999 | US | women whose unborn | 36 | | | DHA+ARA vs Control | Trial randomized parallel | 4 years | Visual acuity Left Eye | SMD | 0.371920019 | Primary
Birch, 2007 | 1993-1999 | US | women whose unborn | 35 | | | DHA vs Control | Trial randomized parallel | 4 years | Visual acuity Left Eye | SMD | 0.508636236 | Primary
Birch, 2007 | 1993-1999 | US | women whose unborn | 35 | | | DHA vs Control | Trial randomized parallel | 4 years | Visual acuity Right Eye | SMD | 0.606300414 | Primary
Birch, 2007 | 1993-1999 | US | women whose unborn | 36 | | | DHA+ARA vs Control | Trial randomized parallel | 4 years | Visual acuity Right Eye | SMD | 0.495647401 | Primary
Birch, 2005 | Not reported | US | Healthy infants | | | | | Trial randomized parallel | | | | | Primary
Birch, 2005 | Not reported | US | Healthy infants | | | | | Trial randomized parallel | | | | | Secondary
2011 | October 2005 | Norway | Preterm infants | | | intervention[64.2 | | Trial randomized parallel | | Index | | | Secondary
2011 | October 2005 | Norway | Preterm infants | 82 | | intervention[64.2 | DHA + AA group vs Placebo | Trial randomized parallel | 20 months | Index (MDI) | SMD | 0.049930181 | Secondary
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | average time/look | SMD | 1.399999976 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | average time/look | SMD | 2.166666746 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | average time/look | SMD | 3.073954344 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | looks to familiar | SMD | 3.625 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | looks to familiar | SMD | 3.299999952 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | looks to familiar | SMD | 3.555555582 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | looks to novel | SMD | 3 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | looks to novel | SMD | 3.799999952 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | looks to novel | SMD | 3.637486458 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | novel time | SMD | 3.279394627 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | novel time | SMD | 0.443887442 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | novel time | SMD | 0 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | time to familiar | SMD | -3.526503086 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | time to familiar | SMD | 0 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | time to familiar | SMD | -0.105032891 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | time to novel | SMD | 0.583333314 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | time to novel | SMD | -0.400000006 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | time to novel | SMD | 0.230769232 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | time/familiar look | SMD | -1.199999928 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | time/familiar look | SMD | 1.833333373 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | time/familiar look | SMD | 2.350671053 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | time/novel look | SMD | 2.285714388 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | time/novel look | SMD | 1.760074019 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | time/novel look | SMD | 2.392242908 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | total looks | SMD | 3.925470352 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | total looks | SMD | 4.235293865 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | total looks | SMD | 4.466666698 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | total time | SMD | -1.642857194 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | total time | SMD | -0.342566878 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | total time | SMD | 0.128901288 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | number of total looks | SMD | 0.303032428 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | number of total looks | SMD | 1.803665161 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | number of total looks | SMD | 1.611111164 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 12 months | time/total looks | SMD | -0.833333373 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 6.5 months | time/total looks | SMD | -2.259340525 | Unspecified
Werkman, 1996 | 1987-1990 | US | Preterm infants | 67 | | | and pre-term infant formulas | Trial randomized parallel | 9 months | time/total looks | SMD | -1.378915668 | Unspecified
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | time/look | SMD | 2.011306286 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | looks to familiar | SMD | 2.974162817 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | looks to novel | SMD | 1.541632175 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | novel time | SMD | 2.401223183 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | time to familiar | SMD | -2.538865328 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | time to novel | SMD | 1.098263025 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | time/familiar look | SMD | 0.953569651 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | time/novel look | SMD | 2.811267614 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | total looks | SMD | 2.370370388 | Secondary
Carlson, 1996 | NR (<1995) | US | Preterm infants | 27 | | | DHA supplement vs Placebo | Trial randomized parallel | 12 months | total time | SMD | -0.4828749 | Secondary
2015 | 2005-2012 | Mexico | infants | 802 | | | DHA (algal) vs Placebo | Trial randomized parallel | 5 years | bmi-for-age z score | SMD | 0 | Primary
2015 | 2005-2012 | Mexico | infants | 802 | | | DHA (algal) vs Placebo | Trial randomized parallel | 5 years | height | SMD | -0.022471754 | Primary
2015 | 2005-2012 | Mexico | infants | 802 | | | DHA (algal) vs Placebo | Trial randomized parallel | 5 years | height-for-age z-score | SMD | 0 | Primary
2015 | 2005-2012 | Mexico | infants | 802 | | | DHA (algal) vs Placebo | Trial randomized parallel | 5 years | weight | SMD | -0.033333335 | Primary
2015 | 2005-2012 | Mexico | infants | 802 | | | DHA (algal) vs Placebo | Trial randomized parallel | 5 years | weight-for-age z-score | SMD | -0.090909086 | Primary
Currie, 2015 | 2003-2011 | US | Healthy infants | 69 | | | DHA < ARA vs Placebo | Trial randomized parallel | 2-6 years | BMI | SMD | 0.1107613 | Secondary
Currie, 2015 | 2003-2011 | US | Healthy infants | 69 | | | DHA < ARA vs Placebo | Trial randomized parallel | 2-6 years | BMI-for-age percentile | SMD | 0.292358667 | Secondary
Currie, 2015 | 2003-2011 | US | Healthy infants | 69 | | | DHA < ARA vs Placebo | Trial randomized parallel | 2-6 years | Length-for-age percentile | SMD | 0.518910348 | Secondary
Currie, 2015 | 2003-2011 | US | Healthy infants | 69 | | | DHA < ARA vs Placebo | Trial randomized parallel | birth-18 months | Length-for-age percentile | SMD | 0.511804104 | Secondary
Currie, 2015 | 2003-2011 | US | Healthy infants | 69 | | | DHA < ARA vs Placebo | Trial randomized parallel | 2-6 years | Weight-for-age percentile | SMD | 0.246899456 | Secondary
Currie, 2015 | 2003-2011 | US | Healthy infants | 69 | | | DHA < ARA vs Placebo | Trial randomized parallel | birth-18 months | Weight-for-age percentile | SMD | 0.246220678 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | ADHD t score (total score) | SMD | -0.064502522 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 583 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | reported) | OR | 0.743847847 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 583 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | disorder | OR | 0.860738277
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | of Intelligence: Full Scale IQ | SMD | -0.013818421 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | of Intelligence: Performance | SMD | 0 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | of Intelligence: Verbal IQ | SMD | -0.053154435 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | Test: Delayed recall raw score | SMD | 0.030764695 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | Test: Delayed recognition | SMD | 0.071062736 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | Test: Total (trials 1-5) correct | SMD | -0.034950692 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | Test: Total intrusions | SMD | -0.106173202 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | Test: Total repetitions | SMD | 0.069810607 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | Test: Trial 1 correct words | SMD | 0.050000001 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | skills: figure ground standard | SMD | -0.049178504 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | skills: visual closure standard | SMD | -0.109523952 | Secondary
Collins, 2015 | 2001-2013 | Australia | Preterm infants | 604 | | | High DHA vs standard DHA | Trial randomized parallel | 7 years | skills: visual discrimination | SMD | 0 | Secondary
Brew, 2015 | September 1997 to 1999-2008 | Australia | Healthy infants | | fish oil, daily, | (DHA+EPA+DPA+A | omega-placebo | Trial randomized parallel | 8-9 years | Program Literacy and | MD | -25.39999962 | Secondary
Brew, 2015 | September 1997 to 1999-2008 | Australia | Healthy infants | | fish oil, daily, | (DHA+EPA+DPA+A | omega-placebo | Trial randomized parallel | 10-11 years | Program Literacy and | MD | -13.69999981 | Secondary
Brew, 2015 | September 1997 to 1999-2008 | Australia | Healthy infants | | fish oil, daily, | (DHA+EPA+DPA+A | omega-placebo | Trial randomized parallel | 12-13 years | Program Literacy and | MD | -11.69999981 | Secondary
Brew, 2015 | September 1997 to 1999-2008 | Australia | Healthy infants | | fish oil, daily, | (DHA+EPA+DPA+A | omega-placebo | Trial randomized parallel | 14-15 years | Program Literacy and | MD | -24.10000038 | Secondary
Brew, 2015 | September 1997 to 1999-2008 | Australia | Healthy infants | | fish oil, daily, | (DHA+EPA+DPA+A | omega-placebo | Trial randomized parallel | 14-15 years | Program Literacy and | MD | -19.89999962 | Secondary
Brew, 2015 | September 1997 to 1999-2008 | Australia | Healthy infants | | fish oil, daily, | (DHA+EPA+DPA+A | omega-placebo | Trial randomized parallel | 8-9 years | Program Literacy and | MD | -27.03000069 | Secondary
Brew, 2015 | September 1997 to 1999-2008 | Australia | Healthy infants | | fish oil, daily, | (DHA+EPA+DPA+A | omega-placebo | Trial randomized parallel | 10-11 years | Program Literacy and | MD | -3.200000048 | Secondary
Brew, 2015 | September 1997 to 1999-2008 | Australia | Health infants | | fish oil, daily, | (DHA+EPA+DPA+A | omega-placebo | Trial randomized parallel | 12-13 years | Program Literacy and | MD | -7 | Secondary
Min, 2014 | Jan 2008 - Dec 2011 | UK | Pregnant women with type 2 | 59 | | | Placebo, healthy women | Trial randomized parallel | birth | birthweight <1500g | OR | 0.392857134 | Secondary
Min, 2014 | Jan 2008 - Dec 2011 | UK | Pregnant women with type 2 | 59 | | | Placebo, healthy women | Trial randomized parallel | birth | birthweight <2500g | OR | 0.888888896 | Secondary
Min, 2014 | Jan 2008 - Dec 2011 | UK | Pregnant women with type 2 | | | | Placebo, healthy women | Trial randomized parallel | birth | gestational age birth | | NC | Secondary
Min, 2014 | Jan 2008 - Dec 2011 | UK | Pregnant women with type 2 | 59 | | | Placebo, healthy women | Trial randomized parallel | birth | preterm birth | OR | 1.185185194 | Secondary
Judge, 2014 | | US | Healthy pregnant women | 42 | | | DHA group vs Placebo | Trial randomized parallel | 2 weeks | Screening Scale (PDSS) total | SMD | 0.437067092 | Primary
Judge, 2014 | | US | Healthy pregnant women | 42 | | | DHA group vs Placebo | Trial randomized parallel | 3 months | Screening Scale (PDSS) total | SMD | -0.243067458 | Primary
Judge, 2014 | | US | Healthy pregnant women | 42 | | | DHA group vs Placebo | Trial randomized parallel | 6 months | Screening Scale (PDSS) total | SMD | 0.184672386 | Primary
Judge, 2014 | | US | Healthy pregnant women | 42 | | | DHA group vs Placebo | Trial randomized parallel | 6 weeks | Screening Scale (PDSS) total | SMD | -0.01572898 | Primary
Almaas, 2015 | 2003-2014 | Norway | weight infants | 97 | | | Intervention vs Control | Trial randomized parallel | 8 years | of Intelligence: Full Scale IQ | SMD | -0.126807705 | Secondary
Almaas, 2015 | 2003-2014 | Norway | weight infants | 97 | | | Intervention vs Control | Trial randomized parallel | 8 years | of Intelligence: Verbal IQ | SMD | -0.130057693 | Secondary
Almaas, 2015 | 2003-2014 | Norway | weight infants | 97 | | | Intervention vs Control | Trial randomized parallel | 8 years | of Intelligence: performance | SMD | -0.066196062 | Secondary
Ramakrishnan, 2015 | 2005-2009 | Mexico | Healthy pregnant women | 730 | study ref 3364 | | Intervention vs Control | Trial randomized parallel | 18 months | Index | SMD | -0.089780308 | Primary
Ramakrishnan, 2015 | 2005-2009 | Mexico | Healthy pregnant women | 730 | study ref 3364 | | Intervention vs Control | Trial randomized parallel | birth | IUGR | OR | 0.923076928 | Secondary
Ramakrishnan, 2015 | 2005-2009 | Mexico | Healthy pregnant women | 730 | study ref 3364 | | Intervention vs Control | Trial randomized parallel | 18 months | Bayley PDI | SMD | -0.032048468 | Primary
Meldrum, 2015 | followup | Australia | pregnant women | 50 | | | Fish oil vs Placebo | Trial randomized parallel | 12 years | for Children IV | SMD | 0.090011589 | Secondary
Meldrum, 2015 | followup | Australia | pregnant women | 47 | | | Fish oil vs Placebo | Trial randomized parallel | 12 years | Test of Visual-Motor | SMD | 0.126974538 | Secondary
Willatts, 2013 | 1992 | Italy, UK, Belgium | Healthy infants | 147 | | | LC-PUFA | Trial randomized parallel | 6 years | Primary Scale of Intelligence- | SMD | -0.186616465 | Secondary
Willatts, 2013 | 1992 | Italy, UK, Belgium | Healthy infants | 147 | | | LC-PUFA | Trial randomized parallel | 6 year | Primary Scale of Intelligence: | SMD | -0.186616465 | Secondary
Willatts, 2013 | 1992 | Italy, UK, Belgium | Healthy infants | 147 | | | LC-PUFA | Trial randomized parallel | 6 year | Primary Scale of Intelligence: | SMD | -0.11632973 | Secondary
Willatts, 2013 | 1992 | Italy, UK, Belgium | Healthy infants | 147 | | | LC-PUFA | Trial randomized parallel | 6 year | Primary Scale of Intelligence: | SMD | -0.171192899 | Secondary
Colombo, 2013 | 09/03/03-09/25/05 | US | Healthy infants | 39 | | | 0.32% vs 0.00% | Trial randomized parallel | 18 months | Communicative Development | SMD | -0.208973438
Colombo, 2013 | 09/03/03-09/25/05 | US | Healthy infants | 36 | | | 0.64% vs 0.00% | Trial randomized parallel | 18 months | Communicative Development | SMD | 0.306412935
Colombo, 2013 | 09/03/03-09/25/05 | US | Healthy infants | 42 | | | 0.96% vs 0.00% | Trial randomized parallel | 18 months | Communicative Development | SMD | 0.025472023
Colombo, 2013 | 09/03/03-09/25/05 | US | Healthy infants | 84 | | | 0.32-0.96% vs 0.00% | Trial randomized parallel | 6 year | Test of Intelligence: Full Scale | SMD | 0.365765303 | Secondary
Colombo, 2013 | 09/03/03-09/25/05 | US | Healthy infants | 36 | | | 0.64% vs 0.00% | Trial randomized parallel | 18 months | Bayley PDI | SMD | -0.094280906 | Secondary
Colombo, 2013 | 09/03/03-09/25/05 | US | Healthy infants | 42 | | | 0.96% vs 0.00% | Trial randomized parallel | 18 months | Bayley PDI | SMD | -0.043183353 | Secondary
Colombo, 2013 | 09/03/03-09/25/05 | US | Healthy infants | 39 | | | 0.32% vs 0.00% | Trial randomized parallel | 18 months | Bayley PDI | SMD | -0.090301 | Secondary
Colombo, 2013 | 09/03/03-09/25/05 | US | Healthy infants | | | | | Trial randomized parallel | | Communicative Development | | | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | birth | birth weight | SMD | 0.202062249 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 2.5 years | Scales: Eye and hand | SMD | 0.554988265 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 2.5 years | Scales: Performance | SMD | 0.384841085 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 2.5 years | Scales: Practical reasoning | SMD | 0.047382046 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 2.5 years | Scales: Speech and hearing | SMD | 0.160580263 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 2.5 years | Scales: General quotient | SMD | 0.361256063 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 2.5 years | Scales: Personal social | SMD | 0.256749153 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 2.5 years | Scales:Locomotor | SMD | 0.370407909 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 72 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | birth | gestational age | SMD | 0.1875 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 64 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 30 months | head circumference | SMD | -0.24137193 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 64 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 30 months | length | SMD | 0.117093936 | Secondary
Dunstan, 2008 | 2000-2003 | Australia | women with allergies | 64 | | erythrocyte (as % | Fish oil vs Control | Trial randomized parallel | 30 months | weight | SMD | 0.200000003 | Secondary
Drover, 2011 | 2003-2006 | US | Healthy infants | 57 | | | (Control) | Trial randomized parallel | 18 months | Development II (Mental | SMD | 0.569579899 | Secondary
Drover, 2011 | 2003-2006 | US | Healthy infants | 60 | | | (Control) | Trial randomized parallel | 18 months | Development II (Mental | SMD | 0.506325007 | Secondary
Drover, 2011 | 2003-2006 | US | Healthy infants | 56 | | | (Control) | Trial randomized parallel | 18 months | Development II (Mental | SMD | 0.335613608 | Secondary
Courville, 2011 | nr | US | Healthy pregnant women | 47 | intake (mg/d), | | DHA-FF vs Placebo | Trial randomized parallel | birth | birth weight | SMD | 0.3114959 | Unspecified
Courville, 2011 | nr | US | Healthy pregnant women | 47 | intake (mg/d), | | DHA-FF vs Placebo | Trial randomized parallel | birth | gestational age | SMD | 0.433120996 | Unspecified
Carlson, 2013 | 2006.01-2011.10 | US | Healthy pregnant women | 301 | intake from | DHA (placebo group | DHA vs Placebo | Trial randomized parallel | birth | birth weight | SMD | 0.305268943 | Primary
Carlson, 2013 | 2006.01-2011.10 | US | Healthy pregnant women | 301 | intake from | DHA (placebo group | DHA vs Placebo | Trial randomized parallel | during pregnancy | preeclampsia | OR | 1 | Secondary
Carlson, 2013 | 2006.01-2011.10 | US | Healthy pregnant women | 301 | intake from | DHA (placebo group | DHA vs Placebo | Trial randomized parallel | birth | birthweight <1500g | OR | 11.51608086 | Secondary
Carlson, 2013 | 2006.01-2011.10 | US | Healthy pregnant women | 301 | intake from | DHA (placebo group | DHA vs Placebo | Trial randomized parallel | birth | birthweight <2500g | OR | 2.307692289 | Secondary
Carlson, 2013 | 2006.01-2011.10 | US | Healthy pregnant women | 301 | intake from | DHA (placebo group | DHA vs Placebo | Trial randomized parallel | birth | gestational age | SMD | 0.202394068 | Primary
Carlson, 2013 | 2006.01-2011.10 | US | Healthy pregnant women | 301 | intake from | DHA (placebo group | DHA vs Placebo | Trial randomized parallel | birth | incidence of premature birth | OR | 1.134920597 | Secondary
Birch, 2010 | 2003-2006 | US | Healthy infants | | | | | Trial randomized parallel | | | | | Primary
Isaacs, 2011 | through 1997 with 10-year followup | UK | Preterm infants | 107 | | | formula vs control | Trial randomized parallel | 10 years | Children: Attention scaled | SMD | -0.039157018 | Secondary
Isaacs, 2011 | through 1997 with 10-year followup | UK | Preterm infants | 107 | | | formula vs control | Trial randomized parallel | 10 years | Children: Creature counting | SMD | 0.166753545 | Secondary
Isaacs, 2011 | through 1997 with 10-year followup | UK | Preterm infants | 107 | | | formula vs control | Trial randomized parallel | 10 years | Children: Dual-task | SMD | 0.112603858 | Secondary
Isaacs, 2011 | through 1997 with 10-year followup | UK | Preterm infants | 107 | | | formula vs control | Trial randomized parallel | 10 years | Children: Opposite Worlds | SMD | 0.158926487 | Secondary
Isaacs, 2011 | through 1997 with 10-year followup | UK | Preterm infants | 107 | | | formula vs control | Trial randomized parallel | 10 years | Children: Score! Scale scored | SMD | -0.029411763 | Secondary
Isaacs, 2011 | through 1997 with 10-year followup | UK | Preterm infants | 107 | | | formula vs control | Trial randomized parallel | 10 years | of Intelligence: FSIQ | SMD | 0.188561812 | Secondary
Isaacs, 2011 | through 1997 with 10-year followup | UK | Preterm infants | 107 | | | formula vs control | Trial randomized parallel | 10 years | of Intelligence: Performance | SMD | -0.022280326 | Secondary
Isaacs, 2011 | through 1997 with 10-year followup | UK | Preterm infants | 107 | | | formula vs control | Trial randomized parallel | 10 years | of Intelligence: VIQ | SMD | 0.318237037 | Secondary
Agostoni, 2009 | 2005; 1-year followup | Italy | Healthy infants | 958 | | | DHA vs placebo | Trial randomized parallel | varies | hands-and-knees crawling | SMD | 0.079347178 | Primary
Agostoni, 2009 | 2005; 1-year followup | Italy | Healthy infants | 1093 | | | DHA vs placebo | Trial randomized parallel | varies | sitting without support | SMD | 0.357142866 | Primary
Agostoni, 2009 | 2005; 1-year followup | Italy | Healthy infants | 1091 | | | DHA vs placebo | Trial randomized parallel | varies | standing alone | SMD | 0.114615023 | Primary
Agostoni, 2009 | 2005; 1-year followup | Italy | Healthy infants | 1091 | | | DHA vs placebo | Trial randomized parallel | varies | walking alone | SMD | 0.133323327 | Primary
Pietrantoni, 2014 | nr | Italy | Healthy pregnant women | 255 | | | DHA group vs Placebo | Trial randomized parallel | birth | membranes | OR | 4.095238209 | Unspecified
Bergmann, 2012 | 2000-2009 | Germany | Healthy infants | 115 | | see refid 2803 | prebiotic | Trial randomized parallel | 6 yrs | BMI | SMD | 0.145546764 | Secondary
Bergmann, 2012 | 2000-2009 | Germany | Healthy infants | 115 | | see refid 2803 | prebiotic | Trial randomized parallel | 6 yrs | head circumference | SMD | -0.14149338 | Secondary
Bergmann, 2012 | 2000-2009 | Germany | Healthy infants | 115 | | see refid 2803 | prebiotic | Trial randomized parallel | 6 yrs | height | SMD | -0.082315855 | Secondary
Bergmann, 2012 | 2000-2009 | Germany | Health infants | 115 | | see refid 2803 | prebiotic | Trial randomized parallel | 6 yrs | weight | SMD | 0.033643577 | Secondary
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | birth | birth weight | SMD | -0.252969831 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | birth | gestational age | SMD | -0.270222873 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 1 month | bmi | SMD | -0.046814039 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 21 months | bmi | SMD | -0.290478349 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 3 months | bmi | SMD | 0.178672299 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 1 month | head circumference | SMD | -0.090714887 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 21 months | head circumference | SMD | 0.238690883 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 3 months | head circumference | SMD | 0 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 1 month | length | SMD | 0.135425761 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 21 months | length | SMD | 0.021943457 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 3 months | length | SMD | -0.037192132 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 1 month | weight | SMD | 0.035049614 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 21 months | weight | SMD | -0.3739416 | Unspecified
Lucia Bergmann, 2007 | 2000-2002 | Germany | pregnant women | 117 | | identified fatty acid | minerals | Trial randomized parallel | 3 months | weight | SMD | 0.081977032 | Unspecified
Furuhjelm, 2011 | 2003-2007 | Sweden | pregnant women | 119 | | | w-3 group vs Placebo | Trial randomized parallel | 2 years | any food reactions | OR | 2.215384722 | Primary
Furuhjelm, 2011 | 2003-2007 | Sweden | pregnant women | 119 | | | w-3 group vs Placebo | Trial randomized parallel | 2 years | any eczema | OR | 1.586014032 | Primary
Furuhjelm, 2011 | 2003-2007 | Sweden | pregnant women | 119 | | | w-3 group vs Placebo | Trial randomized parallel | 2 years | any asthma | OR | 0.949450553 | Primary
Furuhjelm, 2011 | 2003-2007 | Sweden | pregnant women | 119 | | | w-3 group vs Placebo | Trial randomized parallel | 2 years | any rhinoconjunctivitis | OR | 0.830769241 | Primary
Makrides, 2010 | 2005-2008 | Australia | Healthy pregnant women | 2399 | | | capsules | Trial randomized parallel | 6 months | Depression Scale (EPDS) > | OR | 1.180698156 | Primary
Makrides, 2010 | 2005-2008 | Australia | Healthy pregnant women | 2399 | | | capsules | Trial randomized parallel | 6 weeks | Depression Scale (EPDS) > | OR | 1.132153988 | Primary
Makrides, 2010 | 2005-2008 | Australia | Healthy pregnant women | | | | | Trial randomized parallel | | | | | Secondary
Makrides, 2010 | 2005-2008 | Australia | Healthy pregnant women | 726 | | | capsules | Trial randomized parallel | 18 months | Development III (Cognitive | SMD | 0.005061553 | Primary
Makrides, 2010 | 2005-2008 | Australia | Healthy pregnant women | 2399 | | | capsules | Trial randomized parallel | birth | birthweight <2500g | OR | 1.530193567 | Secondary
Makrides, 2010 | 2005-2008 | Australia | Healthy pregnant women | | | | capsules | Trial randomized parallel | birth | gestational age | | NC | Secondary
Makrides, 2010 | 2005-2008 | Australia | Healthy pregnant women | 2399 | | | capsules | Trial randomized parallel | birth | incidence of premature birth | OR | 1.307969332 | Secondary
Llorente, 2003 | <2002 | US | Breast-feeding women | 89 | | saturated 49.7 ± 2.3 | omega 3 capsule vs placebo | Trial randomized parallel | 2 months | (BDI) | SMD | -0.258840621 | Unspecified
Llorente, 2003 | <2002 | US | Breast-feeding women | 89 | | saturated 49.7 ± 2.3 | omega 3 capsule vs placebo | Trial randomized parallel | 3 weeks | (BDI) | SMD | -0.15330784 | Unspecified
Llorente, 2003 | <2002 | US | Breast-feeding women | 89 | | saturated 49.7 ± 2.3 | omega 3 capsule vs placebo | Trial randomized parallel | 4 months | (BDI) | SMD | -0.179693267 | Unspecified
Llorente, 2003 | <2002 | US | Breast-feeding women | 63 | | saturated 49.7 ± 2.3 | omega 3 capsule vs placebo | Trial randomized parallel | 18 months | Depression Scale (EPDS) | SMD | 0 | Unspecified
Llorente, 2003 | <2002 | US | Breast-feeding women | 89 | | saturated 49.7 ± 2.3 | omega 3 capsule vs placebo | Trial randomized parallel | at either 2, 4 or 18 months | responder: BDI<10 | OR | 0.962025285 | Unspecified
Llorente, 2003 | <2002 | US | Breast-feeding women | 89 | | saturated 49.7 ± 2.3 | omega 3 capsule vs placebo | Trial randomized parallel | at either 2, 4 or 18 months | responder: BDI<20 | OR | 0.953926683 | Unspecified
Palmer, 2012 | 2006-2009 | Australia | allergies | 706 | | | Placebo | Trial randomized parallel | 1 year | food allergy with sensitization | OR | 1.088757396 | Primary
Palmer, 2012 | 2006-2009 | Australia | allergies | 706 | | | Placebo | Trial randomized parallel | 1 year | eczema with sensitization | OR | 1.633136153 | Primary
Palmer, 2012 | 2006-2009 | Australia | allergies | 706 | | | Placebo | Trial randomized parallel | 1 year | respiratory tract infection | OR | 1.105507493 | Secondary
Field, 2008 | NR | Canada | Healthy infants | 30 | | | Formula (unsuppl) | Trial randomized parallel | 6 wk | head circumference | SMD | 0.25981921 | Secondary
Field, 2008 | NR | Canada | Healthy infants | 30 | | | (unsuppl) | Trial randomized parallel | 6 wk | head circumference | SMD | -0.157534748 | Secondary
Field, 2008 | NR | Canada | Healthy infants | 30 | | | (unsuppl) | Trial randomized parallel | 6 wk | length | SMD | 0 | Secondary
Field, 2008 | NR | Canada | Healthy infants | 30 | | | Formula (unsuppl) | Trial randomized parallel | 6 wk | length | SMD | 0.773905993 | Secondary
Field, 2008 | NR | Canada | Healthy infants | 30 | | | (unsuppl) | Trial randomized parallel | 6 wk | weight | SMD | 0.28197214 | Secondary
Field, 2008 | NR | Canada | Healthy infants | 30 | | | Formula (unsuppl) | Trial randomized parallel | 6 wk | weight | SMD | 0.261061996 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 188 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | birth | birth weight | SMD | 0.344324082 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 188 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | birth | incidence of premature birth | OR | 1.277777791 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 188 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | birth | gestational age | SMD | 0.475911558 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 170 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 12 months | bmi | SMD | 0.137736201 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 174 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 4 months | bmi | SMD | 0.222069964 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 180 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 6 weeks | bmi | SMD | -0.076762483 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 170 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 12 months | head circumference | SMD | 0.257732689 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 174 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 4 months | head circumference | SMD | 0.15384616 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 179 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 6 weeks | head circumference | SMD | -0.347412616 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 170 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 12 months | length | SMD | 0.230509579 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 175 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 4 months | length | SMD | 0.095156431 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 180 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 6 weeks | length | SMD | 0.172204271 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 170 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 12 months | weight | SMD | 0.263134122 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 174 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 4 months | weight | SMD | 0.246487647 | Secondary
Hauner, 2012 | july 14 2006 - may 22 2009 | Germany | Healthy pregnant women | 180 | records | profile in RBCs at | Intervention vs Control | Trial randomized parallel | 6 weeks | weight | SMD | 0.092580557 | Secondary
Fang, 2005 | NR | Taiwan | Preterm infants | 27 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 1 year | Index | SMD | 1.081910968 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 27 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 6 months | Index | SMD | 0.470003933 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 27 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 12 months | development index | SMD | 1.355769992 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 27 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 6 months | development index | SMD | 0.583425582 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 27 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 4 months | Hiding Heidi Analysis <100% | OR | 1.71875 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 27 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 6 months | Hiding Heidi Analysis <100% | OR | 1.109243751 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 27 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 4 months | cycles per degree | OR | 1.370242238 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 27 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 6 months | cycles per degree | OR | 1.2890625 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 24 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 4 months | Visual evoked potential | SMD | 0.565511107 | Primary
Fang, 2005 | NR | Taiwan | Preterm infants | 23 | | | Neoangelac Plus vs placebo | Trial randomized parallel | 6 months | Visual evoked potential | SMD | 0.155423433 | Primary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | 143 | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | birth | birth weighty | SMD | 0.188516736 | Primary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 4 years | for Children (K-ABC): mental | | NC | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 7 years | for Children (K-ABC): mental | | NC | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 4 years | for Children (K-ABC): non- | | NC | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 7 years | for Children (K-ABC): non- | | NC | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 4 years | for Children (K-ABC): | | NC | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 7 years | for Children (K-ABC): | | NC | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 4 years | for Children (K-ABC): | | NC | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 7 years | for Children (K-ABC): | | NC | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | 143 | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 7 years | bmi | SMD | 0.058823526 | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | 143 | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 7 years | length | SMD | -0.20782125 | Secondary
Helland, 2008 | 1994-2003 | Norway | pregnant women Breast- | 143 | cod n147 corn | cod(n148) corn | corn oil vs Cod oil | Trial randomized parallel | 7 years | weight | SMD | -0.04878049 | Secondary
Gustafson, 2013 | may 2009 - july 2011 | US | pregnant women | 46 | | TFA) placebo group: | DHA vs Placebo | Trial randomized parallel | birth | birth weight | SMD | -0.038860865 | Secondary
Gustafson, 2013 | may 2009 - july 2011 | US | pregnant women | 27 | | TFA) placebo group: | DHA vs Placebo | Trial randomized parallel | 1-14 days post-partum | Assessment: state | SMD | 0.148237228 | Primary
Gustafson, 2013 | may 2009 - july 2011 | US | pregnant women | 27 | | TFA) placebo group: | DHA vs Placebo | Trial randomized parallel | 1-14 days post-partum | Assessment: autonomic | SMD | 0.211658597 | Primary
Gustafson, 2013 | may 2009 - july 2011 | US | pregnant women | 27 | | TFA) placebo group: | DHA vs Placebo | Trial randomized parallel | 1-14 days post-partum | Assessment: motor | SMD | 0.192501962 | Primary
Gustafson, 2013 | may 2009 - july 2011 | US | pregnant women | 27 | | TFA) placebo group: | DHA vs Placebo | Trial randomized parallel | 1-14 days post-partum | Assessment: reflexes | SMD | 0.047278289 | Primary
Gustafson, 2013 | may 2009 - july 2011 | US | pregnant women | 27 | | TFA) placebo group: | DHA vs Placebo | Trial randomized parallel | 1-14 days post-partum | Assessment: state regulation | SMD | 0.025446042 | Primary
Gustafson, 2013 | may 2009 - july 2011 | US | pregnant women | 27 | | TFA) placebo group: | DHA vs Placebo | Trial randomized parallel | 1-14 days post-partum | Assessment:habituation | SMD | -0.156438708 | Primary
Gustafson, 2013 | may 2009 - july 2011 | US | pregnant women | 27 | | TFA) placebo group: | DHA vs Placebo | Trial randomized parallel | 1-14 days post-partum | Assessment:orienting | SMD | 0.21324341 | Primary
Ramakrishnan, 2010 | feb 2005 - f eb 2007 | Mexico | Healthy pregnant women | 973 | LA: 17,846 in | | DHA vs Controls | Trial randomized parallel | birth | birth weight | SMD | 0.011284063 | Primary
Ramakrishnan, 2010 | feb 2005 - f eb 2007 | Mexico | Healthy pregnant women | 973 | LA: 17,846 in | | DHA vs Controls | Trial randomized parallel | birth | birthweight <2500g | OR | 1.002057672 | Secondary
Ramakrishnan, 2010 | feb 2005 - f eb 2007 | Mexico | Healthy pregnant women | 973 | LA: 17,846 in | | DHA vs Controls | Trial randomized parallel | birth | gestational age | SMD | -0.055466857 | Primary
Ramakrishnan, 2010 | feb 2005 - f eb 2007 | Mexico | Healthy pregnant women | 973 | LA: 17,846 in | | DHA vs Controls | Trial randomized parallel | birth | incidence of premature birth | OR | 0.818006218 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 117 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | Preschool Scale of | SMD | -0.229631856 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 117 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | Preschool Scale of | SMD | -0.046969224 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 117 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | Preschool Scale of | SMD | 0.093054555 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 117 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | Preschool Scale of | SMD | -0.15384616 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 113 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | Motor Integration | SMD | -0.108042359 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 115 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | for Children: hand movement | SMD | -0.233761802 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 115 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | McCarthy (leg coordination) | SMD | -0.058601439 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 116 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | (dominant hand) | SMD | -0.088986464 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | 116 | | | omega 3 capsule vs placebo | Trial randomized parallel | 5 years | dominant hand) | SMD | 0 | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | | | | | Trial randomized parallel | | (number of letters correct) | | | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | | | | | Trial randomized parallel | | (number of letters correct) | | | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | | | | | Trial randomized parallel | | Sweep VEP acuity | | | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | | | | | Trial randomized parallel | | VEP Amplitude | | | Secondary
Jensen, 2010 | NR (<2010) | US | Breast-feeding women | | | | | Trial randomized parallel | | sizes) | | | Secondary
Meldrum, 2012 | through October 2008 | Australia | allergies | 287 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Toddler Development (BSID- | SMD | 0.144145399 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 287 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Toddler Development (BSID- | SMD | 0.05327452 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 128 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 12 months | Communicative Development | SMD | 0.219934821 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 161 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Communicative Development | SMD | 0.081229486 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 128 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 12 months | Communicative Development | SMD | 0.493831664 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 161 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Communicative Development | SMD | 0.356752485 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 128 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 12 months | Communicative Development | SMD | -0.041587263 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 161 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Communicative Development | SMD | 0.113986336 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 128 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 12 months | Communicative Development | SMD | 0.448788583 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 161 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Communicative Development | SMD | 0.357071489 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 128 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 12 months | Communicative Development | SMD | 0.072471201 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 161 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Communicative Development | SMD | -0.155814633 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 128 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 12 months | Communicative Development | SMD | 0.137528867 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 161 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Communicative Development | SMD | 0.096759267 | Primary
Meldrum, 2012 | through October 2008 | Australia | allergies | 269 | food | Fish oil group LA, | fish oil capsul vs placebo | Trial randomized parallel | 18 months | Checklist: Sleep problems - | OR | 0.896551728 | Primary
de Jong, 2012 | through October 1999, follow-up 9 | Netherlands | Healthy infants | | | | | Trial randomized parallel | | | | | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 133 | | | (DHASCO) vs placebo | Trial randomized parallel | 30 months | Developmental Index | SMD | 0.577999294 | Primary
Jensen, 2005 | <2004 | US | Breast-feeding women | 147 | | | (DHASCO) vs placebo | Trial randomized parallel | 30 months | Auditory Milestone Scale | SMD | 0.013285638 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 162 | | | (DHASCO) vs placebo | Trial randomized parallel | 12 months | Auditory Milestone Scale | SMD | -0.136091054 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 147 | | | (DHASCO) vs placebo | Trial randomized parallel | 30 months | development quotient (CAT | SMD | -0.022587707 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 162 | | | (DHASCO) vs placebo | Trial randomized parallel | 12 months | development quotient (CAT | SMD | -0.096314266 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 147 | | | (DHASCO) vs placebo | Trial randomized parallel | 30 months | development quotient (DQ) | SMD | -0.147750855 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 162 | | | (DHASCO) vs placebo | Trial randomized parallel | 12 months | development quotient (DQ) | SMD | 0.169517517 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 160 | | | (DHASCO) vs placebo | Trial randomized parallel | 4 months | Sweep VEP | SMD | 0 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 147 | | | (DHASCO) vs placebo | Trial randomized parallel | 4 months | Teller Acuity Card procedure | SMD | 0.47184062 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 147 | | | (DHASCO) vs placebo | Trial randomized parallel | 8 months | Teller Acuity Card procedure | SMD | -2.180923462 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 168 | | | (DHASCO) vs placebo | Trial randomized parallel | 4 months | amplitude | SMD | -0.359262765 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 153 | | | (DHASCO) vs placebo | Trial randomized parallel | 8 months | amplitude | SMD | -0.361061066 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 168 | | | (DHASCO) vs placebo | Trial randomized parallel | 4 months | latency | SMD | -0.080524042 | Secondary
Jensen, 2005 | <2004 | US | Breast-feeding women | 153 | | | (DHASCO) vs placebo | Trial randomized parallel | 8 months | latency | SMD | 0.021418762 | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | fish oil vs placebo | design | 6.5 years | Battery for Children: Mental | | NC | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | placebo | design | 6.5 years | Battery for Children: Mental | | NC | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | folic acid vs placebo | design | 6.5 years | Battery for Children: Mental | | NC | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | fish oil vs placebo | design | 6.5 years | Battery for Children: | | NC | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | placebo | design | 6.5 years | Battery for Children: | | NC | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | folic acid vs placebo | design | 6.5 years | Battery for Children: | | NC | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | fish oil vs placebo | design | 6.5 years | Battery for Children: | | NC | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | placebo | design | 6.5 years | Battery for Children: | | NC | Secondary
Campoy, 2011 | NR, <2011 | Germany, Spain, Hungary | Healthy pregnant women | | | mean DHA Placebo | folic acid vs placebo | design | 6.5 years | Battery for Children: | | NC | Secondary
Mihrshahi, 2003 | 1997-2002 | Australia | allergies | 554 | | | control or intervention vs Diet | Trial randomized parallel | 18 months | eczema or dermatitis | OR | 1 | Primary
Mihrshahi, 2003 | 1997-2002 | Australia | allergies | 554 | | | control or intervention vs Diet | Trial randomized parallel | 18 months | asthma | OR | 1 | Primary
Mihrshahi, 2003 | 1997-2002 | Australia | allergies | 554 | | | control or intervention vs Diet | Trial randomized parallel | 18 months | wheeze ever | OR | 1 | Primary
Toelle, 2010 | 1997-2008 | Australia | Healthy infants | 450 | | | vs Control | Trial randomized parallel | 8 yrs | atopy | OR | 0.995192289 | Primary
Toelle, 2010 | 1997-2008 | Australia | Healthy infants | 450 | | | vs Control | Trial randomized parallel | 8 yrs | rhinitis | OR | 0.97077924 | Secondary
Toelle, 2010 | 1997-2008 | Australia | Healthy infants | 450 | | | vs Control | Trial randomized parallel | 8 yrs | eczema | OR | 0.925974011 | Secondary
Toelle, 2010 | 1997-2008 | Australia | Healthy infants | 450 | | | vs Control | Trial randomized parallel | 8 yrs | asthma | OR | 0.807017565 | Primary
Toelle, 2010 | 1997-2008 | Australia | Healthy infants | 450 | | | vs Control | Trial randomized parallel | 8 yrs | wheeze | OR | 0.730386078 | Primary
Innis, 2008 | NR, <2008 | Canada | Healthy pregnant women | 135 | assignment: | baseline values for | DHA supplement vs placebo | Trial randomized parallel | 60 days | (visual acuity) | SMD | 0.316226661 | Secondary
Smithers, 2010 | 2003 | Australia | Preterm infants | 127 | | | DHA vs Placebo | Trial randomized parallel | 26 months CA | Development Inventory | SMD | -0.043016009 | Secondary
Knudsen, 2006 | 2001- | Denmark | Healthy pregnant women | 972 | EPA+DHA, | and AA in | 03 vs CG | Trial randomized parallel | birth | gestational age | SMD | -0.076467894 | Primary
Knudsen, 2006 | 2001- | Denmark | Healthy pregnant women | 977 | EPA+DHA, | and AA in | 01 vs CG | Trial randomized parallel | birth | gestational age | SMD | 0.075525202 | Primary
Knudsen, 2006 | 2001- | Denmark | Healthy pregnant women | 960 | EPA+DHA, | and AA in | 14 vs CG | Trial randomized parallel | birth | gestational age | SMD | 0 | Primary
Knudsen, 2006 | 2001- | Denmark | Healthy pregnant women | 935 | EPA+DHA, | and AA in | 28 vs CG | Trial randomized parallel | birth | gestational age | SMD | -0.080774717 | Primary
Knudsen, 2006 | 2001- | Denmark | Healthy pregnant women | 970 | EPA+DHA, | and AA in | 07 vs CG | Trial randomized parallel | birth | gestational age | SMD | -0.008395271 | Primary
Knudsen, 2006 | 2001- | Denmark | Healthy pregnant women | 924 | EPA+DHA, | and AA in | c18 vs CG | Trial randomized parallel | birth | gestational age | SMD | 0.008391659 | Primary
Olsen, 2008 | 1989-2006 | Denmark | Healthy pregnant women | 399 | | | Fish oil vs Control | Trial randomized parallel | 16 years | asthma (all types) | OR | 2.659007311 | Secondary
Olsen, 2008 | 1989-2006 | Denmark | Healthy pregnant women | 265 | | | No oil vs Control | Trial randomized parallel | 16 years | asthma (all types) | OR | 3.477941275 | Secondary
Olsen, 2008 | 1989-2006 | Denmark | Healthy pregnant women | 399 | | | Fish oil vs Control | Trial randomized parallel | 16 years | asthma (allergic) | OR | 7.735294342 | Secondary
Olsen, 2008 | 1989-2006 | Denmark | Healthy pregnant women | 265 | | | No oil vs Control | Trial randomized parallel | 16 years | asthma (allergic) | OR | 16.13138771 | Secondary
Cheatham, 2011 | 1998-2007 | Denmark | Healthy infants | 63 | | | Olive oil vs Fish oil | Observational prospective | 7.5 years | Stroop scores | SMD | -0.161422551 | Secondary
Cheatham, 2011 | 1998-2007 | Denmark | Healthy infants | 63 | | | Olive oil vs Fish oil | Observational prospective | 7.5 years | Standardized speed of | SMD | -0.230769232 | Secondary
Furuhjelm, 2009 | 2003-2006 | Sweden | pregnant women | 117 | 0.2g/day EPA- | mean(sd) mol % | w3 group vs Placebo | Trial randomized parallel | 12 months | Food Allergy | OR | 8 | Primary
Furuhjelm, 2009 | 2003-2006 | Sweden | pregnant women | 115 | 0.2g/day EPA- | mean(sd) mol % | w3 group vs Placebo | Trial randomized parallel | 12 months | IgE associated eczema | OR | 3.095238209 | Primary
Furuhjelm, 2009 | 2003-2006 | Sweden | pregnant women | 117 | 0.2g/day EPA- | mean(sd) mol % | w3 group vs Placebo | Trial randomized parallel | 6 months | IgE associated eczema | OR | 2.599999905 | Primary
Dunstan, 2003 | 1999-2001 | Australia | pregnant women | 83 | | | group | Trial randomized parallel | 1 year | food allergy | OR | 1.550387621 | Secondary
Dunstan, 2003 | 1999-2001 | Australia | pregnant women | 83 | | | group | Trial randomized parallel | 1 year | atopic dermatitis | OR | 0.671834648 | Secondary
Dunstan, 2003 | 1999-2001 | Australia | pregnant women | 83 | | | group | Trial randomized parallel | 1 year | asthma | OR | 2.790697575 | Secondary
Dunstan, 2003 | 1999-2001 | Australia | pregnant women | 83 | | | group | Trial randomized parallel | 1 year | chronic cough | OR | 2.04651165 | Secondary
Dunstan, 2003 | 1999-2001 | Australia | pregnant women | 83 | | | group | Trial randomized parallel | 1 year | recurrent wheeze | OR | 1.116279125 | Secondary
Zhou, 2012 | 10. 2005 - 01. 2008 | Australia | Healthy pregnant women | 2399 | | | DHA vs control | Trial randomized parallel | birth | birth weight | SMD | 0.119289018 | Secondary
Zhou, 2012 | 10. 2005 - 01. 2008 | Australia | Healthy pregnant women | 2399 | | | DHA vs control | Trial randomized parallel | during pregnancy | preeclampsia | OR | 0.96264559 | Secondary
Zhou, 2012 | 10. 2005 - 01. 2008 | Australia | Healthy pregnant women | 2399 | | | DHA vs control | Trial randomized parallel | during pregnancy | hypertension | OR | 1.087294936 | Secondary
Zhou, 2012 | 10. 2005 - 01. 2008 | Australia | Healthy pregnant women | 2399 | | | DHA vs control | Trial randomized parallel | birth | SGA for weight | OR | 1.11861515 | Secondary
Zhou, 2012 | 10. 2005 - 01. 2008 | Australia | Healthy pregnant women | 2399 | | | DHA vs control | Trial randomized parallel | birth | birthweight <2500g | OR | 1.530193567 | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | 646 | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | hyperactivity disorder | OR | NC
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | 646 | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | diagnosis of autism | OR | 0.531948865
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Executive Function- | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | Score | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | efficiency) | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | second edition (DAS II) score: | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | second edition (DAS II) score: | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | second edition (DAS II) score: | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | second edition (DAS II) score: | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | second edition (DAS II) score: | | NC | Secondary
Makrides, 2014 | 25, 2012 | Australia | Healthy pregnant women | | | | DHA supplement vs Placebo | Trial randomized parallel | 4 years | second edition (DAS II) score: | | NC | Secondary
de Jong, 2010 | 1997-2008 | Netherlands | Healthy infants | 214 | | | group | Trial randomized parallel | 9 years | neurologically normal | OR | 1.062009454 | Unspecified
Clandinin, 2005 | NR | Canada | Preterm infants | 114 | | | Fish-DHA vs Control | Trial randomized parallel | 118 weeks | Development II (Mental | SMD | 0.661334515 | Unspecified
Clandinin, 2005 | NR | Canada | Preterm infants | 112 | | | Reference vs Control | Trial randomized parallel | 118 weeks | Development II (Mental | SMD | 1.402211308 | Unspecified
Clandinin, 2005 | NR | Canada | Preterm infants | 98 | | | Algal-DHA vs Control | Trial randomized parallel | 118 weeks | Development II (Mental | SMD | 0.426311731 | Unspecified
Clandinin, 2005 | NR | Canada | Preterm infants | 113 | | | Fish-DHA vs Control | Trial randomized parallel | 118 weeks | Development II (Physical | SMD | 0.332264096 | Unspecified
Clandinin, 2005 | NR | Canada | Preterm infants | 113 | | | Reference vs Control | Trial randomized parallel | 118 weeks | Development II (Physical | SMD | 0.996792257 | Unspecified
Clandinin, 2005 | NR | Canada | Preterm infants | 100 | | | Algal-DHA vs Control | Trial randomized parallel | 118 weeks | Development II (Physical | SMD | 0.352404565 | Unspecified
Clandinin, 2005 | NR | Canada | Preterm infants | | | | | Trial randomized parallel | | | | | Unspecified
Stein, 2011 | 02. 2005- 02.2007 | Mexico | Healthy infants | 739 | | | DHA vs Placebo | Trial randomized parallel | birth | birth weight | SMD | 0.047999464 | Primary
Stein, 2011 | 02. 2005- 02.2007 | Mexico | Healthy infants | 737 | | | DHA vs Placebo | Trial randomized parallel | birth | retardation); birth weight for | OR | 0.977006674 | Secondary
Stein, 2011 | 02. 2005- 02.2007 | Mexico | Healthy infants | 739 | | | DHA vs Placebo | Trial randomized parallel | birth | birthweight <2500g | OR | 1.255813956 | Secondary
Stein, 2011 | 02. 2005- 02.2007 | Mexico | Healthy infants | 737 | | | DHA vs Placebo | Trial randomized parallel | birth | gestational age | SMD | 0 | Primary
Stein, 2011 | 02. 2005- 02.2007 | Mexico | Healthy infants | 737 | | | DHA vs Placebo | Trial randomized parallel | birth | incidence of premature birth | OR | 0.911561251 | Secondary
Stein, 2011 | 02. 2005- 02.2007 | Mexico | Healthy infants | 739 | | | DHA vs Placebo | Trial randomized parallel | 18 months | head circumference | SMD | 0 | Primary
Stein, 2011 | 02. 2005- 02.2007 | Mexico | Healthy infants | 739 | | | DHA vs Placebo | Trial randomized parallel | 18 months | length | SMD | 0.035714287 | Primary
Stein, 2011 | 02. 2005- 02.2007 | Mexico | Healthy infants | 739 | | | DHA vs Placebo | Trial randomized parallel | 18 months | weight | SMD | 0 | Primary
Manley, 2011 | 2001-2007 | Australia | feeding women | 481 | | | diet | Trial randomized parallel | 12 months | hay fever | OR | 2.422489882 | Secondary
Manley, 2011 | 2001-2007 | Australia | feeding women | 475 | | | diet | Trial randomized parallel | 12 or 18 months | hay fever | OR | 2.485143423 | Secondary
Manley, 2011 | 2001-2007 | Australia | feeding women | 603 | | | diet | Trial randomized parallel | 18 months | hay fever | OR | 1.341295362 | Secondary
Manley, 2011 | 2001-2007 | Australia | feeding women | 481 | | | diet | Trial randomized parallel | 12 months | eczema | OR | 1.285140514 | Secondary
Manley, 2011 | 2001-2007 | Australia | feeding women | 484 | | | diet | Trial randomized parallel | 12 or 18 months | eczema | OR | 1.045214176 | Secondary
Manley, 2011 | 2001-2007 | Australia | feeding women | 603 | | | diet | Trial randomized parallel | 18 months | eczema | OR | 0.997588396 | Secondary
Manley, 2011 | 2001-2007 | Australia | feeding women | 481 | | | diet | Trial randomized parallel | 12 months | asthma | OR | 1.294065118 | Secondary
Manley, 2011 | 2001-2007 | Australia | feeding women | 489 | | | diet | Trial randomized parallel | 12 or 18 months | asthma | OR | 1.060536981 | Secondary
Manley, 2011 | 2001-2007 | Australia | feeding women | 603 | | | diet | Trial randomized parallel | 18 months | asthma | OR | 1.05340755 | Secondary
Smithers, 2008 | 2001-2004 | Australia | Preterm infants | 115 | begun at birth: | | Treatment vs Control group | Trial randomized parallel | 2 months (corrected age) | Visual evoked potential acuity | SMD | 0 | Primary
Smithers, 2008 | 2001-2004 | Australia | Preterm infants | 95 | begun at birth: | | Treatment vs Control group | Trial randomized parallel | 4 months (corrected age) | Visual evoked potential acuity | SMD | 0.492770821 | Primary
Smithers, 2008 | 2001-2004 | Australia | Preterm infants | 125 | begun at birth: | | Treatment vs Control group | Trial randomized parallel | 4 months (corrected age) | latency: 48 min of arc | SMD | 0.130434781 | Secondary
Smithers, 2008 | 2001-2004 | Australia | Preterm infants | 124 | begun at birth: | | Treatment vs Control group | Trial randomized parallel | 2 months (corrected age) | latency: 69 min of arc | SMD | 0.249258399 | Secondary
Smithers, 2008 | 2001-2004 | Australia | Preterm infants | 125 | begun at birth: | | Treatment vs Control group | Trial randomized parallel | 4 months (corrected age) | latency: 69 min of arc | SMD | 0.09735848 | Secondary
Smithers, 2008 | 2001-2004 | Australia | Preterm infants | 124 | begun at birth: | | Treatment vs Control group | Trial randomized parallel | 2 months (corrected age) | latency: 96 min of arc | SMD | 0.233990356 | Secondary
Smithers, 2008 | 2001-2004 | Australia | Preterm infants | | begun at birth: | | | Trial randomized parallel | | | | | Secondary
Henriksen, 2008 | 2003-2006 | Norway | Preterm infants | | | | | Trial randomized parallel | | Ages and Stages | | | Primary
Henriksen, 2008 | 2003-2006 | Norway | Preterm infants | 105 | | | Intervention vs Control | Trial randomized parallel | 6 months | Communication | SMD | -0.14034833
Henriksen, 2008 | 2003-2006 | Norway | Preterm infants | 105 | | | Intervention vs Control | Trial randomized parallel | 6 months | Ages and Stages: Fine motor | SMD | -0.047187887
Henriksen, 2008 | 2003-2006 | Norway | Preterm infants | 105 | | | Intervention vs Control | Trial randomized parallel | 6 months | motor | SMD | 0.212538749
Henriksen, 2008 | 2003-2006 | Norway | Preterm infants | 105 | | | Intervention vs Control | Trial randomized parallel | 6 months | social | SMD | 0.079742588
Henriksen, 2008 | 2003-2006 | Norway | Preterm infants | 105 | | | Intervention vs Control | Trial randomized parallel | 6 months | solving | SMD | 0.464068025
Henriksen, 2008 | 2003-2006 | Norway | Preterm infants | 105 | | | Intervention vs Control | Trial randomized parallel | 6 months | Ages and Stages: Total | SMD | 0.167406961
Henriksen, 2008 | 2003-2006 | Norway | Preterm infants | 100 | | | Intervention vs Control | Trial randomized parallel | day 65 | head circumference | SMD | 0.350823224 | Secondary
Noakes, 2012 | Not reported | UK | Healthy pregnant women | 86 | | | group | Trial randomized parallel | 6 months | atopic dermatitis | OR | 1.357142806 | Primary
Noakes, 2012 | Not reported | UK | Healthy pregnant women | 83 | | | group | Trial randomized parallel | 6 months | chest infection | OR | 0.268115938 | Secondary
Noakes, 2012 | Not reported | UK | Healthy pregnant women | 83 | | | group | Trial randomized parallel | 6 months | pneumonia/bronchiolitis | OR | 0.804347813 | Secondary
Noakes, 2012 | Not reported | UK | Healthy pregnant women | 83 | | | group | Trial randomized parallel | 6 months | wheeze | OR | 1.263975143 | Secondary
Fleddermann, 2014 | Jan 2010 to May 2011 | Serbia | Healthy infants | 164 | | | Control Formula (CF) | Trial randomized parallel | days | head circumference gain | SMD | 0 | Secondary
Fleddermann, 2014 | Jan 2010 to May 2011 | Serbia | Healthy infants | 164 | | | Control Formula (CF) | Trial randomized parallel | days | length gain | SMD | 0.5 | Secondary
Fleddermann, 2014 | Jan 2010 to May 2011 | Serbia | Healthy infants | 164 | | | Control Formula (CF) | Trial randomized parallel | days | weight gain | SMD | 0.29683876 | Primary
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | birth | birth weight | SMD | 0.031639852 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 73 | | | DHA+AA vs placebo | Trial randomized parallel | birth | birth weight | SMD | 0.163081348 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | 18 months | Development (Mental | SMD | -0.121097274 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | 18 months | development index | SMD | 0.405259818 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 73 | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | development index | SMD | 0.081668519 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | | | | DHA vs placebo | Trial randomized parallel | 18 months | fluency score | | NC | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | fluency score | | NC | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | neurological optimality score | | NC | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | | | | DHA vs placebo | Trial randomized parallel | 18 months | neurological optimality score | | NC | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 73 | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | neurological dysfunction | OR | 1.147058845 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | 18 months | neurological dysfunction | OR | 2.00980401 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | 18 months | neurological condition | OR | 0.995121956 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 73 | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | neurological condition | OR | 1.220512867 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | 18 months | neurological dysfunction | OR | 0.775210083 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 73 | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | neurological dysfunction | OR | 1.720588207 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 73 | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | head circumference | SMD | -0.207277015 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | 18 months | head circumference | SMD | -0.154297054 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | 18 months | length | SMD | -0.278005928 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 73 | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | length | SMD | -0.119455278 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 73 | | | DHA+AA vs placebo | Trial randomized parallel | 18 months | weight | SMD | 0 | Unspecified
Goor, 2011 | 2004-2009 | Netherlands | Healthy infants | 75 | | | DHA vs placebo | Trial randomized parallel | 18 months | weight | SMD | -0.157088354 | Unspecified
Bouwstra, 2005 | 1997-2002 | Netherlands | Healthy infants | 290 | | | group | Trial randomized parallel | 18 months | Development (Mental | SMD | -0.177778691 | Secondary
Bouwstra, 2005 | 1997-2002 | Netherlands | Healthy infants | 315 | | | group | Trial randomized parallel | 18 months | Bayley PDI | SMD | -0.11104764 | Secondary
Bouwstra, 2005 | 1997-2002 | Netherlands | Healthy infants | | | | group | Trial randomized parallel | 18 months | neurological optimality score | | NC | Secondary
Bouwstra, 2005 | 1997-2002 | Netherlands | Healthy infants | 315 | | | group | Trial randomized parallel | 18 months | neurological dysfunction | OR | 0.69112426 | Secondary
Bouwstra, 2003 | 1997-1999 | Netherlands | Healthy infants | 250 | | | formula | Trial randomized parallel | 3 months | movements | OR | 1.631578922 | Primary
Bouwstra, 2003 | 1997-1999 | Netherlands | Healthy infants | 250 | | | formula | Trial randomized parallel | 3 months | movements | OR | 0.857142806 | Primary
Judge, 2012 | nr | US | Healthy pregnant women | 48 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | birth | birth weight | SMD | 0.395035178 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | (AS, %) | SMD | -0.233474881 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | (AS, %) | SMD | -0.009735975 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | Sleep Transition (AQST, %) | SMD | 0.187375277 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | Sleep Transition (AQST, %) | SMD | 0.207601592 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | (Ar/AS) | SMD | 0.654765487 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | (Ar/AS) | SMD | 0.090548791 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | (Ar/QS) | SMD | 0.733264267 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | (Ar/QS) | SMD | 0.470817834 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | Period (LSP, min) | SMD | 0.442723185 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | Period (LSP, min) | SMD | -0.10683021 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | Period (MSP, min) | SMD | 0.110412516 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | Period (MSP, min) | SMD | -0.007233827 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | (W, %) | SMD | 0.155022875 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | (W, %) | SMD | 0.105503738 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | (QS,%) | SMD | 0.154997826 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | (QS,%) | SMD | -0.183042795 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | length (ASBL, min) | SMD | -0.008501874 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | length (ASBL, min) | SMD | -0.063578799 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | Sleep Ratio(AS:QS) | SMD | 0.278755456 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | Sleep Ratio(AS:QS) | SMD | 0.039062161 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | length (QSBL, min) | SMD | 0.171680912 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | length (QSBL, min) | SMD | -0.296015859 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 46 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 1 day after birth | Transition (T, %) | SMD | 0.251199126 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 39 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | 2 days after birth | Transition (T, %) | SMD | 0.458189279 | Secondary
Judge, 2012 | nr | US | Healthy pregnant women | 48 | | phospholipid (PL) | DHA vs Placebo | Trial randomized parallel | birth | gestational age | SMD | 0.446485102 | Secondary
Judge, 2007 | | US | Healthy pregnant women | 29 | | | DHA vs placebo | Trial randomized parallel | birth | birth weight | SMD | 0.632310689 | Secondary
Judge, 2007 | | US | Healthy pregnant women | 29 | | | DHA vs placebo | Trial randomized parallel | birth | gestational age | SMD | 0.989868045 | Secondary
Malcolm, 2003 | | NR | NR | 37 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 50 weeks (corrected age) | components of the transient | SMD | 0.179844633 | Primary
Malcolm, 2003 | | NR | NR | 47 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 66 weeks (corrected age) | components of the transient | SMD | -0.492338538 | Primary
Malcolm, 2003 | | NR | NR | 9 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | birth | components of the transient | SMD | 1.108460188 | Primary
Malcolm, 2003 | | NR | NR | 52 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 50 weeks (corrected age) | components of the transient | SMD | -0.341469467 | Primary
Malcolm, 2003 | | NR | NR | 51 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 66 weeks (corrected age) | components of the transient | SMD | -0.199502796 | Primary
Malcolm, 2003 | | NR | NR | 49 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | birth | components of the transient | SMD | -0.126309648 | Primary
Malcolm, 2003 | | NR | NR | 34 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 50 weeks (corrected age) | components of the transient | SMD | 0.716261685 | Primary
Malcolm, 2003 | | NR | NR | 26 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 66 weeks (corrected age) | components of the transient | SMD | -0.424542576 | Primary
Malcolm, 2003 | | NR | NR | 53 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | birth | components of the transient | SMD | 0.111686088 | Primary
Malcolm, 2003 | | NR | NR | 45 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 50 weeks (corrected age) | components of the transient | SMD | 0.17894046 | Primary
Malcolm, 2003 | | NR | NR | 51 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 66 weeks (corrected age) | components of the transient | SMD | -0.202426881 | Primary
Malcolm, 2003 | | NR | NR | 14 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | birth | components of the transient | SMD | 0.521966219 | Primary
Malcolm, 2003 | | NR | NR | 47 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 50 weeks (corrected age) | components of the transient | SMD | -0.060580112 | Primary
Malcolm, 2003 | | NR | NR | 31 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | 66 weeks (corrected age) | components of the transient | SMD | 0.047604621 | Primary
Malcolm, 2003 | | NR | NR | 55 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | birth | components of the transient | SMD | -0.003236139 | Primary
Malcolm, 2003 | | NR | NR | 55 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | (postconceptional age) | head circumference | SMD | -0.103399284 | Secondary
Malcolm, 2003 | | NR | NR | 55 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | age) | head circumference | SMD | -0.143804684 | Secondary
Malcolm, 2003 | | NR | NR | 55 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | (postconceptional age) | length | SMD | -0.18173489 | Secondary
Malcolm, 2003 | | NR | NR | 55 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | age) | length | SMD | -0.206196889 | Secondary
Malcolm, 2003 | | NR | NR | 55 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | (postconceptional age) | weight | SMD | -0.135403872 | Secondary
Malcolm, 2003 | | NR | NR | 55 | | fish oil and placebo | DHA vs Placebo | Trial randomized parallel | age) | weight | SMD | -0.498577684 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 103 | | | Fish oil vs Olive oil | Trial randomized parallel | 2 months | bmi | SMD | -0.145485193 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 101 | | | High fish vs Olive oil | Trial randomized parallel | 2 months | bmi | SMD | -0.21977061 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 57 | | | High fish vs Olive oil | Trial randomized parallel | 2.5 years | bmi | SMD | 0.218214259 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 70 | | | Fish oil vs Olive oil | Trial randomized parallel | 2.5 years | bmi | SMD | 0.57349366 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 95 | | | High fish vs Olive oil | Trial randomized parallel | 4 months | bmi | SMD | -0.279849559 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 98 | | | Fish oil vs Olive oil | Trial randomized parallel | 4 months | bmi | SMD | -0.074872986 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 95 | | | High fish vs Olive oil | Trial randomized parallel | 9 months | bmi | SMD | -0.25416404 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 100 | | | Fish oil vs Olive oil | Trial randomized parallel | 9 months | bmi | SMD | 0.195860922 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 107 | | | High fish vs Olive oil | Trial randomized parallel | 1 week | head circumference | SMD | 0.295087546 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 110 | | | Fish oil vs Olive oil | Trial randomized parallel | 1 week | head circumference | SMD | 0.278649122 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 97 | | | High fish vs Olive oil | Trial randomized parallel | 2 months | head circumference | SMD | 0.329351515 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 100 | | | Fish oil vs Olive oil | Trial randomized parallel | 2 months | head circumference | SMD | 0.352829069 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 59 | | | High fish vs Olive oil | Trial randomized parallel | 2.5 years | head circumference | SMD | 0.683686197 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 71 | | | Fish oil vs Olive oil | Trial randomized parallel | 2.5 years | head circumference | SMD | 0.539367497 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 91 | | | Fish oil vs Olive oil | Trial randomized parallel | 4 months | head circumference | SMD | 0.2894862 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 91 | | | High fish vs Olive oil | Trial randomized parallel | 4 months | head circumference | SMD | 0.446112722 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 97 | | | Fish oil vs Olive oil | Trial randomized parallel | 9 months | head circumference | SMD | 0.380636931 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 87 | | | High fish vs Olive oil | Trial randomized parallel | 9 months | head circumference | SMD | 0.376579493 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 57 | | | High fish vs Olive oil | Trial randomized parallel | 2.5 years | length | SMD | 0.365219474 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 70 | | | Fish oil vs Olive oil | Trial randomized parallel | 2.5 years | length | SMD | -0.022575691 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 98 | | | Fish oil vs Olive oil | Trial randomized parallel | 4 months | length | SMD | 0.089712508 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 96 | | | High fish vs Olive oil | Trial randomized parallel | 4 months | length | SMD | 0.350786001 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 100 | | | Fish oil vs Olive oil | Trial randomized parallel | 9 months | length | SMD | 0.230778441 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 95 | | | High fish vs Olive oil | Trial randomized parallel | 9 months | length | SMD | 0.296311766 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | | | | High fish vs Olive oil | Trial randomized parallel | 2 months | length | | NC | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | | | | Fish oil vs Olive oil | Trial randomized parallel | 2 months | length | | NC | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 72 | | | Fish oil vs Olive oil | Trial randomized parallel | 2.5 years | weight | SMD | 0.357142866 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 59 | | | High fish vs Olive oil | Trial randomized parallel | 2.5 years | weight | SMD | 0.349132419 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 100 | | | Fish oil vs Olive oil | Trial randomized parallel | 4 months | weight | SMD | 0 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 96 | | | High fish vs Olive oil | Trial randomized parallel | 4 months | weight | SMD | -0.091694273 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 95 | | | High fish vs Olive oil | Trial randomized parallel | 9 months | weight | SMD | -0.04347815 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | 100 | | | Fish oil vs Olive oil | Trial randomized parallel | 9 months | weight | SMD | 0.297872335 | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | | | | Fish oil vs Olive oil | Trial randomized parallel | 2 months | weight | | NC | Secondary
Lauritzen, 2005 | 2000 Follow-up 2.5 years | Denmark | Breast-feeding women | | | | High fish vs Olive oil | Trial randomized parallel | 2 months | weight | | NC | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 80 | LCPUFA/d | | placebo group | Trial randomized parallel | 9 months | solving) | SMD | -0.058045622 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 86 | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 9 months | solving) | SMD | -0.060069013 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 79 | LCPUFA/d | | placebo group | Trial randomized parallel | 1 year | Development Inventory | SMD | 0.142857149 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 89 | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 1 year | Development Inventory | SMD | -0.15545632 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | | LCPUFA/d | | placebo group | Trial randomized parallel | 2 years | Development Inventory | | NC | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 2 years | Development Inventory | | NC | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 2 years | Development Inventory | | NC | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | | LCPUFA/d | | placebo group | Trial randomized parallel | 2 years | Development Inventory | | NC | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | | LCPUFA/d | | placebo group | Trial randomized parallel | 1 year | Development Inventory | | NC | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 1 year | Development Inventory | | NC | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 89 | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 1 year | Development Inventory | OR | 0.75 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 79 | LCPUFA/d | | placebo group | Trial randomized parallel | 1 year | Development Inventory | OR | 1.041666627 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 89 | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 1 year | Development Inventory | SMD | 0 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 79 | LCPUFA/d | | placebo group | Trial randomized parallel | 1 year | Development Inventory | SMD | 0 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 71 | LCPUFA/d | | placebo group | Trial randomized parallel | 2 years | Development Inventory | OR | 1.010638356 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 71 | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 2 years | Development Inventory | OR | 0.797872365 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 71 | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 2 years | Development Inventory | OR | 0.78125 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 71 | LCPUFA/d | | placebo group | Trial randomized parallel | 2 years | Development Inventory | OR | 1.25 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 89 | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 1 year | Development Inventory | SMD | -0.419727713 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 79 | LCPUFA/d | | placebo group | Trial randomized parallel | 1 year | Development Inventory | SMD | -0.141472399 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 71 | LCPUFA/d | | placebo group | Trial randomized parallel | 2 years | Development Inventory | SMD | 0.102434091 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | 71 | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 2 years | Development Inventory | SMD | -0.342880517 | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | | LCPUFA/d | | fish oil vs placebo group | Trial randomized parallel | 1 year | Development Inventory | | NC | Secondary
Lauritzen, 2005 | enrolled in 1999 | Denmark | feeding women | | LCPUFA/d | | placebo group | Trial randomized parallel | 1 year | Development Inventory | | NC | Secondary
Lauritzen, 2004 | 1999 | Denmark | lower than average fish | 88 | LCPUFA | | FO Intervention vs Placebo | Trial randomized parallel | 2 months | (SWEEP-VEP) | SMD | 0 | Primary
Lauritzen, 2004 | 1999 | Denmark | lower than average fish | 97 | LCPUFA | | FO Intervention vs Placebo | Trial randomized parallel | 4 months | (SWEEP-VEP) | SMD | 0.235909283 | Primary
Smithers, 2011 | August 2008 | Australia | pregnant women | 182 | | | placebo | Trial randomized parallel | 4 months | VEP Latency: 20 min of arc | SMD | 0 | Secondary
Smithers, 2011 | August 2008 | Australia | pregnant women | 182 | | | placebo | Trial randomized parallel | 4 months | VEP Latency: 48 min of arc | SMD | 0 | Secondary
Smithers, 2011 | August 2008 | Australia | pregnant women | 182 | | | placebo | Trial randomized parallel | 4 months | VEP Latency: 69 min of arc | SMD | 0.117291354 | Secondary
Smithers, 2011 | August 2008 | Australia | pregnant women | 182 | | | placebo | Trial randomized parallel | 4 months | VEP acuity (adjusted) | SMD | -0.09137056 | Primary
Smithers, 2011 | August 2008 | Australia | pregnant women | 182 | | | placebo | Trial randomized parallel | 4 months | VEP acuity (unadjusted) | SMD | -0.090627246 | Primary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 79 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | 26-28 weeks | (BDI) | SMD | -0.164675847 | Primary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 80 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | 26-28 weeks | (BDI) | SMD | -0.592749 | Primary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 79 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | 34-36 weeks | (BDI) | SMD | 0.084774867 | Primary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 80 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | 34-36 weeks | (BDI) | SMD | -0.142899796 | Primary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 80 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | 6-8 weeks post-partum | (BDI) | SMD | -0.123252839 | Primary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 79 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | 6-8 weeks post-partum | (BDI) | SMD | 0.036273193 | Primary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 78 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | birth | birth weight | SMD | 0.92729032 | Secondary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 80 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | birth | birth weight | SMD | 0.168324068 | Secondary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 79 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | during pregnancy | preeclampsia | OR | 2.317073107 | Secondary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 80 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | during pregnancy | preeclampsia | OR | 0.594512224 | Secondary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 80 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | birth | gestational age | SMD | 0 | Secondary
Mozurkewich, 2013 | Oct 2008 - may 2011 | US | Healthy pregnant women | 79 | | 0.29+-0.18; DHA | Control/Placebo | Trial randomized parallel | birth | gestational age | SMD | 1.041483521 | Secondary
Makrides, 2009 | 2005 | Australia | feeding women | 657 | | | tuna oil capsules vs Placebo | Trial randomized parallel | 18 months | Development (Mental | SMD | 0.118830428 | Primary
Makrides, 2009 | 2005 | Australia | feeding women | 657 | | | tuna oil capsules vs Placebo | Trial randomized parallel | 18 months | development index | SMD | 0.06171966 | Secondary
Unay, 2004 | 2000-2001 | Turkey | Healthy infants | 44 | | | Formula A vs Formula B | Trial randomized parallel | 16 weeks | potentials: interpeak latency I- | SMD | 0.598671079 | Unspecified
Unay, 2004 | 2000-2001 | Turkey | Healthy infants | 44 | | | Formula A vs Formula B | Trial randomized parallel | 16 weeks | potentials: interpeak latency I- | SMD | 0.773020685 | Unspecified
Unay, 2004 | 2000-2001 | Turkey | Healthy infants | 44 | | | Formula A vs Formula B | Trial randomized parallel | 16 weeks | potentials: interpeak latency III- | SMD | 0.695141316 | Unspecified
Unay, 2004 | 2000-2001 | Turkey | Healthy infants | 44 | | | Formula A vs Formula B | Trial randomized parallel | 16 weeks | potentials: wave I | SMD | 0.59218657 | Unspecified
Unay, 2004 | 2000-2001 | Turkey | Healthy infants | 44 | | | Formula A vs Formula B | Trial randomized parallel | 16 weeks | potentials: wave III | SMD | 1.096204042 | Unspecified
Unay, 2004 | 2000-2001 | Turkey | Healthy infants | 44 | | | Formula A vs Formula B | Trial randomized parallel | 16 weeks | potentials: wave V | SMD | 1.541923404 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 215 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | birth | birth weight | SMD | -0.006778704 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 154 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | Bayley Scales of Infant | OR | 0.9009009 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 154 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | Bayley Scales of Infant | OR | 1.593172073 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 154 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | Bayley Scales of Infant | OR | 1.824324369 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 159 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 14 months | Infant MacArthur | OR | 2.076923132 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 134 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | Infant MacArthur | OR | 1.880136967 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 159 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 14 months | Infant MacArthur | OR | 2.423076868 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 134 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | Infant MacArthur | OR | 2.051058531 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 134 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | Toddler MacArthur | OR | 2.172602654 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 154 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | Bayley Scales of Infant | OR | 1.189189196 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 154 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | Bayley Scales of Infant | OR | 1.132561088 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 176 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 12 months | acuity>==13 cycles/degree | OR | 1.172839522 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 184 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 2 months | acuity>==3.3 cycles/degree | OR | 2.219444513 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 178 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 12 months | length-for-age z score | SMD | -0.303669691 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 158 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | length-for-age z score | SMD | -0.222088635 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 194 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 2 months | length-for-age z score | SMD | -0.113076374 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 196 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 6 months | length-for-age z score | SMD | -0.076164596 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 183 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 9 months | length-for-age z score | SMD | -0.262741685 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 175 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 12 months | weight-for-age z score | SMD | -0.029014073 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 144 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | weight-for-age z score | SMD | -0.059054446 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 191 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 2 months | weight-for-age z score | SMD | -0.231481478 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 196 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 6 months | weight-for-age z score | SMD | -0.150995702 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 181 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 9 months | weight-for-age z score | SMD | 0.009529548 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 174 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 12 months | weight-for-length z score | SMD | 0.173458695 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 144 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 18 months | weight-for-length z score | SMD | 0 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 191 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 2 months | weight-for-length z score | SMD | -0.228453875 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 196 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 6 months | weight-for-length z score | SMD | -0.1455805 | Unspecified
Mulder, 2014 | 2004 to 2008 | Canada | Healthy pregnant women | 181 | 97.5th | Phusphatidylethanol | DHA supplement vs placebo | Trial randomized parallel | 9 months | weight-for-length z score | SMD | 0.206030265 | Unspecified
Escamilla-Nunez, 2014 | 2005-2009 | Mexico | allergies | | (25th, 75th | | | Trial randomized parallel | | breathing difficulty | | | Primary
Escamilla-Nunez, 2014 | 2005-2009 | Mexico | allergies | | (25th, 75th | | | Trial randomized parallel | | cough | | | Primary
Escamilla-Nunez, 2014 | 2005-2009 | Mexico | allergies | 869 | (25th, 75th | | DHA vs Placebo | Trial randomized parallel | 18 months | and/or nasal discharge, fever | OR | 1 | Primary
Escamilla-Nunez, 2014 | 2005-2009 | Mexico | allergies | | (25th, 75th | | | Trial randomized parallel | | wheezing | | | Primary
Harper, 2010 | 01. 2005 - 10. 2006 | US | At risk for preterm labor | | | | DHA+EPA vs placebo | Trial randomized parallel | birth | birth weight | | NC | Secondary
Harper, 2010 | 01. 2005 - 10. 2006 | US | At risk for preterm labor | | | | | Trial randomized parallel | | birthweight <2500g | | | Secondary
Harper, 2010 | 01. 2005 - 10. 2006 | US | At risk for preterm labor | 852 | | | DHA+EPA vs placebo | Trial randomized parallel | during pregnancy | hypertension | OR | 1.043478251 | Secondary
Harper, 2010 | 01. 2005 - 10. 2006 | US | At risk for preterm labor | 837 | | | DHA+EPA vs placebo | Trial randomized parallel | birth | SGA less than 10th percentile | OR | 1.220000029 | Secondary
Harper, 2010 | 01. 2005 - 10. 2006 | US | At risk for preterm labor | 837 | | | DHA+EPA vs placebo | Trial randomized parallel | birth | birthweight <1500g | OR | 1.161632299 | Secondary
Harper, 2010 | 01. 2005 - 10. 2006 | US | At risk for preterm labor | 837 | | | DHA+EPA vs placebo | Trial randomized parallel | birth | birthweight <2500g | OR | 1.240892529
Harper, 2010 | 01. 2005 - 10. 2006 | US | At risk for preterm labor | | | | DHA+EPA vs placebo | Trial randomized parallel | birth | gestational age | | NC | Secondary
Harper, 2010 | 01. 2005 - 10. 2006 | US | At risk for preterm labor | 852 | | | DHA+EPA vs placebo | Trial randomized parallel | birth | incidence of premature birth | OR | 1.101587057 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 900 | | | DHA vs Placebo | Trial randomized parallel | birth | birthweight <2500g | OR | 1.394736886 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 749 | | | DHA vs Placebo | Trial randomized parallel | 1 month | latency 1 | SMD | 0.066548586 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 664 | | | DHA vs Placebo | Trial randomized parallel | 3 months | latency 1 | SMD | 0 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 749 | | | DHA vs Placebo | Trial randomized parallel | 1 month | latency 1-3 | SMD | 0.031397559 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 664 | | | DHA vs Placebo | Trial randomized parallel | 3 months | latency 1-3 | SMD | -0.035714287 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 749 | | | DHA vs Placebo | Trial randomized parallel | 1 month | latency 1-5 | SMD | 0.05330497 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 664 | | | DHA vs Placebo | Trial randomized parallel | 3 months | latency 1-5 | SMD | 0.07692308 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 749 | | | DHA vs Placebo | Trial randomized parallel | 1 month | latency 3 | SMD | 0.030762423 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 664 | | | DHA vs Placebo | Trial randomized parallel | 3 months | latency 3 | SMD | -0.03076845 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 749 | | | DHA vs Placebo | Trial randomized parallel | 1 month | latency 3-5 | SMD | 0 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 664 | | | DHA vs Placebo | Trial randomized parallel | 3 months | latency 3-5 | SMD | 0.088181496 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 749 | | | DHA vs Placebo | Trial randomized parallel | 1 month | latency 5 | SMD | 0.066548586 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 664 | | | DHA vs Placebo | Trial randomized parallel | 3 months | latency 5 | SMD | 0.097546339 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 679 | | | DHA vs Placebo | Trial randomized parallel | 3 months | Amplitude P | SMD | -0.06494198 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 679 | | | DHA vs Placebo | Trial randomized parallel | 6 months | Amplitude P | SMD | -0.014183416 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 679 | | | DHA vs Placebo | Trial randomized parallel | 3 months | Latency N1 | SMD | -0.017955747 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 679 | | | DHA vs Placebo | Trial randomized parallel | 6 months | Latency N1 | SMD | 0.094251022 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 679 | | | DHA vs Placebo | Trial randomized parallel | 3 months | Latency N3 | SMD | 0.096027076 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 679 | | | DHA vs Placebo | Trial randomized parallel | 6 months | Latency N3 | SMD | 0.034909811 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 679 | | | DHA vs Placebo | Trial randomized parallel | 3 months | Latency P1 | SMD | 0.027921384 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | 679 | | | DHA vs Placebo | Trial randomized parallel | 6 months | Latency P1 | SMD | 0.055364583 | Primary
Stein, 2012 | Feb 2005-Feb 2007 | NR | pregnant women | | | | | Trial randomized parallel | | | | | Primary
Lagemaat, 2011 | 2003 - 2006 | Netherlands | weight infants | 87 | | Mean(SD) AA PDF: | HM vs Term Formula (TF) | Trial randomized parallel | term age | head circumference | SMD | -0.13333334 | Unspecified
Lagemaat, 2011 | 2003 - 2006 | Netherlands | weight infants | 93 | | Mean(SD) AA PDF: | PDF vs Term Formula (TF) | Trial randomized parallel | term age | head circumference | SMD | 0.074617639 | Unspecified
Lagemaat, 2011 | 2003 - 2006 | Netherlands | weight infants | 87 | | Mean(SD) AA PDF: | HM vs Term Formula (TF) | Trial randomized parallel | term age | length | SMD | -0.215482861 | Unspecified
Lagemaat, 2011 | 2003 - 2006 | Netherlands | weight infants | 93 | | Mean(SD) AA PDF: | PDF vs Term Formula (TF) | Trial randomized parallel | term age | length | SMD | 0 | Unspecified
Lagemaat, 2011 | 2003 - 2006 | Netherlands | weight infants | 87 | | Mean(SD) AA PDF: | HM vs Term Formula (TF) | Trial randomized parallel | term age | weight | SMD | -0.109594747 | Unspecified
Lagemaat, 2011 | 2003 - 2006 | Netherlands | weight infants | 93 | | Mean(SD) AA PDF: | PDF vs Term Formula (TF) | Trial randomized parallel | term age | weight | SMD | -0.111676455 | Unspecified
D'Vaz, 2012 | 2005-2009 | Australia | allergies | 323 | | | Fish oil group vs Placebo | Trial randomized parallel | 12 months | mediated food allergy, | OR | 1.044960976 | Primary
D'Vaz, 2012 | 2005-2009 | Australia | allergies | 323 | | | Fish oil group vs Placebo | Trial randomized parallel | 12 months | food allergy | OR | 1.229120731 | Primary
D'Vaz, 2012 | 2005-2009 | Australia | allergies | 323 | | | Fish oil group vs Placebo | Trial randomized parallel | 12 months | eczema | OR | 1.041327238 | Primary
D'Vaz, 2012 | 2005-2009 | Australia | allergies | 323 | | | Fish oil group vs Placebo | Trial randomized parallel | 12 months | asthma | OR | NC | Primary
D'Vaz, 2012 | 2005-2009 | Australia | allergies | 323 | | | Fish oil group vs Placebo | Trial randomized parallel | 12 months | persistent cough | OR | 0.845166802 | Primary
D'Vaz, 2012 | 2005-2009 | Australia | allergies | 323 | | | Fish oil group vs Placebo | Trial randomized parallel | 6 months | persistent cough | OR | 1.327450395 | Primary
D'Vaz, 2012 | 2005-2009 | Australia | allergies | 323 | | | Fish oil group vs Placebo | Trial randomized parallel | 12 months | recurrent wheeze | OR | 0.711719394 | Primary
D'Vaz, 2012 | 2005-2009 | Australia | allergies | 323 | | | Fish oil group vs Placebo | Trial randomized parallel | 6 months | recurrent wheeze | OR | 1.096589446 | Primary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 456 | | | High DHA vs standard DHA | Trial randomized parallel | 12 months | head circumference | SMD | -0.055555556 | Secondary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 587 | | | High DHA vs standard DHA | Trial randomized parallel | 18 months | head circumference | SMD | 0 | Secondary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 601 | | | High DHA vs standard DHA | Trial randomized parallel | 4 months | head circumference | SMD | -0.117647052 | Secondary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 465 | | | High DHA vs standard DHA | Trial randomized parallel | 12 months | length | SMD | 0.054768324 | Secondary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 592 | | | High DHA vs standard DHA | Trial randomized parallel | 18 months | length | SMD | 0.177277058 | Secondary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 605 | | | High DHA vs standard DHA | Trial randomized parallel | 4 months | length | SMD | 0.030263307 | Secondary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 471 | | | High DHA vs standard DHA | Trial randomized parallel | 12 months | weight | SMD | 0.085180961 | Secondary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 598 | | | High DHA vs standard DHA | Trial randomized parallel | 18 months | weight | SMD | 0.154532641 | Secondary
Collins, 2011 | 2001-2007 | Australia | women Breast-feeding | 615 | | | High DHA vs standard DHA | Trial randomized parallel | 4 months | weight | SMD | 0.014466298 | Secondary
Escolano-Margarit, 2011 | 2001-2008 | Germany, Spain, Hungary | Healthy pregnant women | 167 | | plasma DHA | fish oil vs placebo | Trial randomized parallel | 5.5 years | Hempel exam | OR | 0.993518531 | Secondary
Escolano-Margarit, 2011 | 2001-2008 | Germany, Spain, Hungary | Healthy pregnant women | 148 | | plasma DHA | fish oil vs placebo | Trial randomized parallel | 5.5 years | Towen exam | OR | 1.000791192 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 849 | | | DHA vs Placebo | Trial randomized parallel | 1 month (preceding 15 days) | nasal congestion, nasal | OR | 1.18617022 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 3 months | nasal congestion, nasal | OR | 1.166666746 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 6 months (preceding 15 days) | nasal congestion, nasal | OR | 1.008658051 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 849 | | | DHA vs Placebo | Trial randomized parallel | 1 month (preceding 15 days) | cough | OR | 1.157894731 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 3 months | cough | OR | 1.238341928 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 6 months (preceding 15 days) | cough | OR | 0.993957698 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 849 | | | DHA vs Placebo | Trial randomized parallel | 1 month (preceding 15 days) | difficulty breathing | OR | 0.958333373 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 3 months | difficulty breathing | OR | 0.827586174 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 6 months (preceding 15 days) | difficulty breathing | OR | 1.214285731 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 849 | | | DHA vs Placebo | Trial randomized parallel | 1 month (preceding 15 days) | nasal congestion | OR | 1.163120627 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 3 months | nasal congestion | OR | 1.131474137 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 6 months (preceding 15 days) | nasal congestion | OR | 0.945945978 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 849 | | | DHA vs Placebo | Trial randomized parallel | 1 month (preceding 15 days) | nasal secretion | OR | 1.521126747 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 3 months | nasal secretion | OR | 1.15436244 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 6 months (preceding 15 days) | nasal secretion | OR | 1.046099305 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 849 | | | DHA vs Placebo | Trial randomized parallel | 1 month (preceding 15 days) | phlegm | OR | 1.142857194 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 3 months | phlegm | OR | 0.953846157 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 6 months (preceding 15 days) | phlegm | OR | 1.012552261 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 849 | | | DHA vs Placebo | Trial randomized parallel | 1 month (preceding 15 days) | wheezing | OR | 0.843373537 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 3 months | wheezing | OR | 1.157142878 | Secondary
Imhoff-Kunsch, 2011 | February 2005 - February 2007 | Mexico | Healthy pregnant women | 834 | | | DHA vs Placebo | Trial randomized parallel | 6 months (preceding 15 days) | wheezing | OR | 0.915966392 | Secondary
Marks, 2006 | 1997-2004 | Australia | allergies | 516 | | | Active vs Diet control | Trial randomized parallel | 5 years | test) | OR | 1.062451601 | Secondary
Marks, 2006 | 1997-2004 | Australia | allergies | 516 | | | Active vs Diet control | Trial randomized parallel | 5 years | rhinitis | OR | 0.985346794 | Secondary
Marks, 2006 | 1997-2004 | Australia | allergies | 516 | | | Active vs Diet control | Trial randomized parallel | 5 years | current eczema | OR | 1.171575189 | Secondary
Marks, 2006 | 1997-2004 | Australia | allergies | 516 | | | Active vs Diet control | Trial randomized parallel | 5 years | cough without cold | OR | 0.701861978 | Secondary
Marks, 2006 | 1997-2004 | Australia | allergies | 516 | | | Active vs Diet control | Trial randomized parallel | 5 years | frequent wheeze | OR | 0.857831299 | Secondary
Marks, 2006 | 1997-2004 | Australia | allergies | 516 | | | Active vs Diet control | Trial randomized parallel | 5 years | probable current asthma | OR | 0.882044315 | Primary
Palmer, 2013 | Domino study) | Australia | of allergy | 706 | | | Fish oil vs Control | Trial randomized parallel | 3 years | allergic rhinitis | OR | 1.209730387 | Primary
Palmer, 2013 | Domino study) | Australia | of allergy | 706 | | | Fish oil vs Control | Trial randomized parallel | 3 years | food allergy | OR | 0.846811295 | Primary
Palmer, 2013 | Domino study) | Australia | of allergy | 706 | | | Fish oil vs Control | Trial randomized parallel | 3 years | eczema | OR | 4.645364761 | Primary
Palmer, 2013 | Domino study) | Australia | of allergy | 706 | | | Fish oil vs Control | Trial randomized parallel | 3 years | asthma | OR | 0.90729785 | Primary
Drover, 2012 | NR | US | Healthy infants | 42 | | | Control group | Trial randomized parallel | 2.5 years | (SRC) | SMD | 0.236179456 | Secondary
Drover, 2012 | NR | US | Healthy infants | 46 | | | Control group | Trial randomized parallel | 2.5 years | (SRC) | SMD | 0.320607185 | Secondary
Drover, 2012 | NR | US | Healthy infants | 43 | | | Control group | Trial randomized parallel | 2.5 years | (SRC) | SMD | 0.394611269 | Secondary
Atwell, 2013 | 2001-2005 | Australia | Preterm infants | 657 | | | High DHA vs Standard DHA | Trial randomized parallel | 18 months | for lower respiratory | OR | 1.094693184 | Secondary
Linnamaa, 2010 | 2004-2008 | Finland | pregnant women | 241 | | | Intervention vs Controls | Trial randomized parallel | birth | birth weight | SMD | -0.008606554 | Secondary
Linnamaa, 2010 | 2004-2008 | Finland | pregnant women | 202 | | | Intervention vs Controls | Trial randomized parallel | 12 months | positive egg skin test | OR | 1.211538434 | Secondary
Linnamaa, 2010 | 2004-2008 | Finland | pregnant women | 166 | | | Intervention vs Controls | Trial randomized parallel | 24 months | positive egg skin test | OR | 1.589080453 | Secondary
Linnamaa, 2010 | 2004-2008 | Finland | pregnant women | 238 | | | Intervention vs Controls | Trial randomized parallel | 3 months | positive egg skin test | OR | 0.888888896 | Secondary
Linnamaa, 2010 | 2004-2008 | Finland | pregnant women | 210 | | | Intervention vs Controls | Trial randomized parallel | 12 months | atopic dermatitis | OR | 1.432506919 | Primary
Linnamaa, 2010 | 2004-2008 | Finland | pregnant women | 177 | | | Intervention vs Controls | Trial randomized parallel | 24 months | atopic dermatitis | OR | 1 | Primary
Linnamaa, 2010 | 2004-2008 | Finland | pregnant women | 241 | | | Intervention vs Controls | Trial randomized parallel | 3 months | atopic dermatitis | OR | 1 | Primary