# Appendix H List of Included Studies From the Original Report

1 Agostoni C, Marangoni F, Giovannini M, et al. (2001). Prolonged breast-feeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol.
2 Agostoni C, Riva E, Trojan S, et al. (1995). Docosahexaenoic acid status and developmental quotient of healthy term infants. Lancet.
3 Agostoni C, Trojan S, Bellu R, et al. (1997). Developmental quotient at 24 months and fatty acid composition of diet in early infancy: a follow up study. Arch Dis Child.
4 Agostoni C, Trojan S, Bellu R, et al. (1995). Neurodevelopmental quotient of healthy term infants at 4 months and feeding practice: the role of long-chain polyunsaturated fatty acids. Pediatr Res.
5 Al MD, van Houwelingen AC, Badart-Smook A, et al. (1995). The essential fatty acid status of mother and child in pregnancy-induced hypertension: a prospective longitudinal study. Am J Obstet Gynecol.
6 Al MD, von Houwelingen AC, Hasaart TH, et al. (1994). The relationship between the essential fatty acid status of mother and child and the occurrence of pregnancy-induced hypertension. Intermediate results of a prospective longitudinal study. World Rev Nutr Diet.
7 Auestad N, Halter R, Hall RT, et al. (2001). Growth and development in term infants fed long-chain polyunsaturated fatty acids: a double-masked, randomized, parallel, prospective, multivariate study. Pediatrics.
8 Auestad N, Montalto MB, Hall RT, et al. (1997). Visual acuity, erythrocyte fatty acid composition, and growth in term infants fed formulas with long chain polyunsaturated fatty acids for one year. Ross Pediatric Lipid Study. Pediatr Res.
9 Auestad N, Scott DT, Janowsky JS, et al. (2003). Visual, cognitive, and language assessments at 39 months: a follow-up study of children fed formulas containing long-chain polyunsaturated fatty acids to 1 year of age. Pediatrics.
10 Birch DG, Birch EE, Hoffman DR, et al. (1992). Retinal development in very-low-birth-weight infants fed diets differing in omega-3 fatty acids. Invest Ophthalmol Vis Sci.
11 Birch E, Birch D, Hoffman D, et al. (1993). Breast-feeding and optimal visual development. J Pediatr Ophthalmol Strabismus.
12 Birch EE, Birch DG, Hoffman DR, et al. (1992). Dietary essential fatty acid supply and visual acuity development. Invest Ophthalmol Vis Sci.
13 Birch EE, Garfield S, Hoffman DR, et al. (2000). A randomized controlled trial of early dietary supply of long-chain polyunsaturated fatty acids and mental development in term infants. Dev Med Child Neurol.
14 Birch EE, Hoffman DR, Castaneda YS, et al. (2002). A randomized controlled trial of long-chain polyunsaturated fatty acid supplementation of formula in term infants after weaning at 6 wk of age. Am J Clin Nutr.
15 Birch EE, Hoffman DR, Uauy R, et al. (1998). Visual acuity and the essentiality of docosahexaenoic acid and arachidonic acid in the diet of term infants. Pediatr Res.
16 Bougle D, Denise P, Vimard F, et al. (1999). Early neurological and neuropsychological development of the preterm infant and polyunsaturated fatty acids supply. Clin Neurophysiol.
17 Bulstra-Ramakers MT, Huisjes HJ, Visser GH. (1995). The effects of 3g eicosapentaenoic acid daily on recurrence of intrauterine growth retardation and pregnancy induced hypertension. Br J Obstet Gynaecol.
18 Carlson SE, Cooke RJ, Rhodes PG, et al. (1991). Long-term feeding of formulas high in linolenic acid and marine oil to very low birth weight infants: phospholipid fatty acids. Pediatr Res.
19 Carlson SE, Cooke RJ, Werkman SH, et al. (1992). First year growth of preterm infants fed standard compared to marine oil n-3 supplemented formula. Lipids.
20 Carlson SE, Ford AJ, Werkman SH, et al. (1996). Visual acuity and fatty acid status of term infants fed human milk and formulas with and without docosahexaenoate and arachidonate from egg yolk lecithin. Pediatr Res.
21 Carlson SE, Rhodes PG, Rao VS, et al. (1987). Effect of fish oil supplementation on the n-3 fatty acid content of red blood cell membranes in preterm infants. Pediatr Res.
22 Carlson SE, Werkman SH. (1996). A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until two months. Lipids.
23 Carlson SE, Werkman SH, Cooke RJ, et al. (1990). Docosahexaenoate (DHA) and eicosapentaenoate (EPA) status of preterm infants: relationship to the Fagantest of Infant Intelligence and the Bayley Scale of Mental Development. FASEB J.
24 Carlson SE, Werkman SH, Peeples JM, et al. (1993). Arachidonic acid status correlates with first year growth in preterm infants. Proc Natl Acad Sci U S A.
25 Carlson SE, Werkman SH, Rhodes PG, et al. (1993). Visual-acuity development in healthy preterm infants: effect of marine-oil supplementation. Am J Clin Nutr.
26 Carlson SE, Werkman SH, Tolley EA. (1996). Effect of long-chain n-3 fatty acid supplementation on visual acuity and growth of preterm infants with and without bronchopulmonary dysplasia. Am J Clin Nutr.
27 Cetin I, Giovannini N, Alvino G, et al. (2002). Intrauterine growth restriction is associated with changes in polyunsaturated fatty acid fetal-maternal relationships. Pediatr Res.
28 Cheruku SR, Montgomery-Downs HE, Farkas SL, et al. (2002). Higher maternal plasma docosahexaenoic acid during pregnancy is associated with more mature neonatal sleep-state patterning. Am J Clin Nutr.
29 Clandinin MT, Aerde J, Boettcher JA, et al. (2002). Growth and development of very-low-birth-weight infants (VLBW) is enhanced by formulas supplemented with docosahexaenoic acid (DHA) and arachidonic acid (ARA). J Pediatr Gastroenterol Nutr.
30 Clandinin MT, Aerde J, Boettcher JA, et al. (2002). Safety of formulas with docosahexaenoic acid (DHA) and arachidonic acid (ARA) from single-cell and marine sources for low-birth-weight infants (LBW). J Pediatr Gastroenterol Nutr.
31 Craig-Schmidt MC, Carlson SE, Crocker L, et al. (1994). Plasma total phospholipid arachidonic acid and eicosapentaenoic acid in normal and hypertensive pregnancy. World Rev Nutr Diet.
32 D'Almeida A, Carter JP, Anatol A, et al. (1992). Effects of a combination of evening primrose oil (gamma linolenic acid) and fish oil (eicosapentaenoic + docahexaenoic acid) versus magnesium, and versus placebo in preventing pre-eclampsia. Women Health.
33 de Groot RH, Adam J, Jolles J, et al. (2004). Alpha-linolenic acid supplementation during human pregnancy does not effect cognitive functioning. Prostaglandins Leukotrienes & Essential Fatty Acids.
34 de Groot RH, Hornstra G, van Houwelingen AC, et al. (2004). Effect of alpha-linolenic acid supplementation during pregnancy on maternal and neonatal polyunsaturated fatty acid status and pregnancy outcome. Am J Clin Nutr.
35 Decsi T, Koletzko B. (1995). Growth, fatty acid composition of plasma lipid classes, and plasma retinol and alpha-tocopherol concentrations in full-term infants fed formula enriched with omega-6 and omega-3 long-chain polyunsaturated fatty acids. Acta Paediatr.
36 Diersen-Schade DA, Hansen JW, Harris CL, et al. (1998). Docosahexaenoic Acid plus Arachidonic Acid Enhance Preterm Growth. Riemersma R, Armstrong R, Kelly RW, Wilson R, editors. Essential Fatty Acids and Eicosanoids-Invited Papers from the Fourth International Congress.
37 Dunstan JA, Mori TA, Barden A, et al. (2004). Effects of n-3 polyunsaturated fatty acid supplementation in pregnancy on maternal and fetal erythrocyte fatty acid composition. Eur J Clin Nutr.
38 Elias SL, Innis SM. (2001). Infant plasma trans, n-6, and n-3 fatty acids and conjugated linoleic acids are related to maternal plasma fatty acids, length of gestation, and birth weight and length. Am J Clin Nutr.
39 Faldella G, Govoni M, Alessandroni R, et al. (1995). Maturation of the visual cortex in relation to dietary intake of polyenoic fatty acids in preterm infants. Bambini e Nutrizione.
40 Faldella G, Govoni M, Alessandroni R, et al. (1996). Visual evoked potentials and dietary long chain polyunsaturated fatty acids in preterm infants. Archives of Disease in Childhood Fetal & Neonatal Edition.
41 Fewtrell MS, Abbott RA, Kennedy K, et al. (2004). Randomized, double-blind trial of long-chain polyunsaturated fatty acid supplementation with fish oil and borage oil in preterm infants. J Pediatr.
42 Fewtrell MS, Morley R, Abbott RA, et al. (2002). Double-blind, randomized trial of long-chain polyunsaturated fatty acid supplementation in formula fed to preterm infants. Pediatrics.
43 Field CJ, Thomson CA, Van Aerde JE, et al. (2000). Lower proportion of CD45R0+ cells and deficient interleukin-10 production by formula-fed infants, compared with human-fed, is corrected with supplementation of long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr.
44 Ghebremeskel K, Burns L, Costeloe K, et al. (1999). Plasma vitamin A and E in preterm babies fed on breast milk or formula milk with or without long-chain polyunsaturated fatty acids. Int J Vitam Nutr Res.
45 Ghys A, Bakker E, Hornstra G, et al. (2002). Red blood cell and plasma phospholipid arachidonic and docosahexaenoic acid levels at birth and cognitive development at 4 years of age. Early Hum Dev.
46 Gibson RA, Neumann MA, Makrides M. (1997). Effect of increasing breast milk docosahexaenoic acid on plasma and erythrocyte phospholipid fatty acids and neural indices of exclusively breast fed infants. Eur J Clin Nutr.
47 Gobel Y, Koletzko B, Bohles HJ, et al. (2003). Parenteral fat emulsions based on olive and soybean oils: a randomized clinical trial in preterm infants. J Pediatr Gastroenterol Nutr.
48 Groh-Wargo S, Moore JJ, Catalano P, et al. (2002). Docosahexaenoic acid (DHA) and arachidonic acid (AA) supplementation does not change body composition in preterm (PT) infants. Pediatr Res.
49 Guesnet P. (1999). Blood lipid concentrations of docosahexaenoic and arachidonic acids at birth determine their relative postnatal changes in term infants fed breast milk or formula. Am J Clin Nutr.
50 Helland IB, Saugstad OD, Smith L, et al. (2001). Similar effects on infants of n-3 and n-6 fatty acids supplementation to pregnant and lactating women. Pediatrics.
51 Helland IB, Smith L, Saarem K, et al. (2003). Maternal supplementation with very-long-chain n-3 fatty acids during pregnancy and lactation augments children's IQ at 4 years of age. Pediatrics.
52 Hoffman DR, Birch EE, Birch DG, et al. (1999). Fatty acid profile of buccal cheek cell phospholipids as an index for dietary intake of docosahexaenoic acid in preterm infants. Lipids.
53 Hoffman DR, Birch EE, Birch DG, et al. (2000). Impact of early dietary intake and blood lipid composition of long-chain polyunsaturated fatty acids on later visual development. J Pediatr Gastroenterol Nutr.
54 Hoffman DR, Birch EE, Birch DG, et al. (1993). Effects of supplementation with omega 3 long-chain polyunsaturated fatty acids on retinal and cortical development in premature infants. Am J Clin Nutr.
55 Hoffman DR, Birch EE, Castaneda YS, et al. (2003). Visual function in breast-fed term infants weaned to formula with or without long-chain polyunsaturates at 4 to 6 months: a randomized clinical trial. J Pediatr.
56 Hofmann M, Bahlmann F, Pollow K, et al. (1998). Phospholipid and triglycerid composition in patients with preeclampsia compared with normal pregnancies - Deficiency of essential polyunsaturated fatty acids. Geburtshilfe Frauenheilkd.
57 Innis SM, Adamkin DH, Hall RT, et al. (2002). Docosahexaenoic acid and arachidonic acid enhance growth with no adverse effects in preterm infants fed formula. J Pediatr.
58 Innis SM, Akrabawi SS, Diersen-Schade DA, et al. (1997). Visual acuity and blood lipids in term infants fed human milk or formulae. Lipids.
59 Innis SM, Gilley J, Werker J. (2001). Are human milk long-chain polyunsaturated fatty acids related to visual and neural development in breast-fed term infants?. J Pediatr.
60 Innis SM, Nelson CM, Rioux MF, et al. (1994). Development of visual acuity in relation to plasma and erythrocyte omega-6 and omega-3 fatty acids in healthy term gestation infants. Am J Clin Nutr.
61 Jensen CL, Prager TC, Fraley JK, et al. (1997). Effect of dietary linoleic/alpha-linolenic acid ratio on growth and visual function of term infants. J Pediatr.
62 Jensen CL, Prager TC, Zou Y, et al. (1999). Effects of maternal docosahexaenoic acid supplementation on visual function and growth of breast-fed term infants. Lipids.
63 Jorgensen MH, Hernell O, Hughes E, et al. (2001). Is there a relation between docosahexaenoic acid concentration in mothers' milk and visual development in term infants?. J Pediatr Gastroenterol Nutr.
64 Jorgensen MH, Hernell O, Lund P, et al. (1996). Visual acuity and erythrocyte docosahexaenoic acid status in breast-fed and formula-fed term infants during the first four months of life. Lipids.
65 Jorgensen MH, Holmer G, Lund P, et al. (1998). Effect of formula supplemented with docosahexaenoic acid and gamma- linolenic acid on fatty acid status and visual acuity in term infants. J Pediatr Gastroenterol Nutr.
66 Koletzko B, Edenhofer S, Lipowsky G, et al. (1995). Effects of a low birthweight infant formula containing human milk levels of docosahexaenoic and arachidonic acids. J Pediatr Gastroenterol Nutr.
67 Koletzko B, Sauerwald U, Keicher U, et al. (2003). Fatty acid profiles, antioxidant status, and growth of preterm infants fed diets without or with long-chain polyunsaturated fatty acids. A randomized clinical trial. Eur J Nutr.
68 Krasevec JM, Jones PJ, Cabrera-Hernandez A, et al. (2002). Maternal and infant essential fatty acid status in Havana, Cuba. Am J Clin Nutr.
69 Laivuori H, Hovatta O, Viinikka L, et al. (1993). Dietary supplementation with primrose oil or fish oil does not change urinary excretion of prostacyclin and thromboxane metabolites in pre-eclamptic women. Prostaglandins Leukotrienes & Essential Fatty Acids.
70 Lapillonne A, Brossard N, Claris O, et al. (2000). Erythrocyte fatty acid composition in term infants fed human milk or a formula enriched with a low eicosapentanoic acid fish oil for 4 months. Eur J Pediatr.
71 Lapillonne A, JC P, V C, et al. (1997). Supplementation of preterm formulas (PTF) with a low EPA fish oil: Effect on polyunsaturated fatty acids(PUFAS) status and growth. J Pediatr Gastroenterol Nutr.
72 Leaf A, Gosbell A, McKenzie L, et al. (1996). Long chain polyunsaturated fatty acids and visual function in preterm infants. Early Hum Dev.
73 Lim M, Antonson D, Clandinin M, et al. (2002). Formulas with docosahexaenoic acid (DHA) and arachidonic acid (ARA) for low-birth weight infants (LBW) are safe. Pediatr Res.
74 Lucas A, Stafford M, Morley R, et al. (1999). Efficacy and safety of long-chain polyunsaturated fatty acid supplementation of infant-formula milk: a randomised trial. Lancet.
75 Makrides M, Neumann M, Simmer K, et al. (1995). Are long-chain polyunsaturated fatty acids essential nutrients in infancy?. Lancet.
76 Makrides M, Neumann MA, Gibson RA. (2001). Perinatal characteristics may influence the outcome of visual acuity. Lipids.
77 Makrides M, Neumann MA, Jeffrey B, et al. (2000). A randomized trial of different ratios of linoleic to alpha-linolenic acid in the diet of term infants: effects on visual function and growth. Am J Clin Nutr.
78 Makrides M, Neumann MA, Simmer K, et al. (1999). Dietary long-chain polyunsaturated fatty acids do not influence growth of term infants: A randomized clinical trial. Pediatrics.
79 Makrides M, Neumann MA, Simmer K, et al. (2000). A critical appraisal of the role of dietary long-chain polyunsaturated fatty acids on neural indices of term infants: a randomized, controlled trial. Pediatrics.
80 Makrides M, Simmer K, Goggin M, et al. (1993). Erythrocyte docosahexaenoic acid correlates with the visual response of healthy, term infants. Pediatr Res.
81 Malcolm CA, Hamilton R, McCulloch DL, et al. (2003). Scotopic electroretinogram in term infants born of mothers supplemented with docosahexaenoic acid during pregnancy. Invest Ophthalmol Vis Sci.
82 Martinez FE, Santos MMd, Sieber VM, et al. (1999). Growth and nitrogen balance in preterm infants fed formula with long chain polyunsaturated fatty acids. Nutr Res.
83 Matorras R, Perteagudo L, Nieto A, et al. (1994). Intrauterine growth retardation and plasma fatty acids in the mother and the fetus. Eur J Obstet Gynecol Reprod Biol.
84 McClead REJ, Meng HC, Gregory SA, et al. (1985). Comparison of the clinical and biochemical effect of increased alpha-linolenic acid in a safflower oil intravenous fat emulsion. J Pediatr Gastroenterol Nutr.
85 Morris G, Moorcraft J, Mountjoy A, et al. (2000). A novel infant formula milk with added long-chain polyunsaturated fatty acids from single-cell sources: a study of growth, satisfaction and health. Eur J Clin Nutr.
86 O'Connor DL, Hall R, Adamkin D, et al. (2001). Growth and development in preterm infants fed long-chain polyunsaturated fatty acids: a prospective, randomized controlled trial. Pediatrics.
87 O'Connor DL, Jacobs J, Hall R, et al. (2003). Growth and development of premature infants fed predominantly human milk, predominantly premature infant formula, or a combination of human milk and premature formula. J Pediatr Gastroenterol Nutr.
88 Olsen SF, Secher NJ, Tabor A, et al. (2000). Randomised clinical trials of fish oil supplementation in high risk pregnancies. Fish Oil Trials In Pregnancy (FOTIP) Team. BJOG.
89 Olsen SF, Soorensen JD, Secher NJ, et al. (1994).
90 Olsen SF, Sorensen JD, Secher NJ, et al. (1992). Randomised controlled trial of effect of fish-oil supplementation on pregnancy duration. Lancet.
91 Onwude JL, Lilford RJ, Hjartardottir H, et al. (1995). A randomised double blind placebo controlled trial of fish oil in high risk pregnancy. Br J Obstet Gynaecol.
92 Ponder DL, Innis SM, Benson JD, et al. (1992). Docosahexaenoic acid status of term infants fed breast milk or infant formula containing soy oil or corn oil. Pediatr Res.
93 Reece MS, McGregor JA, Allen KG, et al. (1997). Maternal and perinatal long-chain fatty acids: possible roles in preterm birth. Am J Obstet Gynecol.
94 Rocquelin G, Tapsoba S, Kiffer J, et al. (2003). Human milk fatty acids and growth of infants in Brazzaville (The Congo) and Ouagadougou (Burkina Faso). Public Health Nutr.
95 Rump P, Mensink RP, Kester AD, et al. (2001). Essential fatty acid composition of plasma phospholipids and birth weight: a study in term neonates. Am J Clin Nutr.
96 Salvig JD, Olsen SF, Secher NJ. (1996). Effects of fish oil supplementation in late pregnancy on blood pressure: a randomised controlled trial. Br J Obstet Gynaecol.
97 Scott DT, Janowsky JS, Carroll RE, et al. (1998). Formula supplementation with long-chain polyunsaturated fatty acids: are there developmental benefits?. Pediatrics.
98 Shouk TA, Omar MN, Fayed ST. (1999). Essential fatty acids profile and lipid peroxides in severe pre-eclampsia. Ann Clin Biochem.
99 Smuts CM, Borod E, Peeples JM, et al. (2003). High-DHA eggs: feasibility as a means to enhance circulating DHA in mother and infant. Lipids.
100 Smuts CM, Huang M, Mundy D, et al. (2003). A randomized trial of docosahexaenoic acid supplementation during the third trimester of pregnancy. Obstet Gynecol.
101 Uauy R, Hoffman DR, Birch EE, et al. (1994). Safety and efficacy of omega-3 fatty acids in the nutrition of very low birth weight infants: soy oil and marine oil supplementation of formula. J Pediatr.
102 Uauy RD, Birch DG, Birch EE, et al. (1990). Effect of dietary omega-3 fatty acids on retinal function of very-low-birth-weight neonates. Pediatr Res.
103 van Wezel-Meijler G, van der Knaap MS, Huisman J, et al. (2002). Dietary supplementation of long-chain polyunsaturated fatty acids in preterm infants: effects on cerebral maturation. Acta Paediatr.
104 Vanderhoof J, Gross S, Hegvi T, et al. (1997). A new arachidonic acid (ARA) and docosahexanoic acid (DHA) supplemented preterm formula: growth and safety assessment. Pediatr Res.
105 Vanderhoof J, Gross S, Hegyi T. (2000). A multicenter long-term safety and efficacy trial of preterm formula supplemented with long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr.
106 Vanderhoof J, Gross S, Hegyi T, et al. (1999). Evaluation of a long-chain polyunsaturated fatty acid supplemented formula on growth, tolerance, and plasma lipids in preterm infants up to 48 weeks postconceptional age. J Pediatr Gastroenterol Nutr.
107 Vilbergsson G, Samsioe G, Wennergren M, et al. (1991). Essential fatty acids in pregnancies complicated by intrauterine growth retardation. Int J Gynaecol Obstet.
108 Vilbergsson G, Wennergren M, Samsioe G, et al. (1994). Essential fatty acid status is altered in pregnancies complicated by intrauterine growth retardation. World Rev Nutr Diet.
109 Voigt RG, Jensen CL, Fraley JK, et al. (2002). Relationship between omega3 long-chain polyunsaturated fatty acid status during early infancy and neurodevelopmental status at 1 year of age. J Hum Nutr Diet.
110 Wang YP, Kay HH, Killam AP. (1991). Decreased levels of polyunsaturated fatty acids in preeclampsia. Am J Obstet Gynecol.
111 Werkman SH, Carlson SE. (1996). A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until nine months. Lipids.
112 Willatts P, Forsyth JS, DiModugno MK, et al. (1998). Influence of long-chain polyunsaturated fatty acids on infant cognitive function. Lipids.
113 Willatts P, Forsyth JS, DiModugno MK, et al. (1998). Effect of long-chain polyunsaturated fatty acids in infant formula on problem solving at 10 months of age. Lancet British edition.
114 Williams C, Birch EE, Emmett PM, et al. (2001). Stereoacuity at age 3.5 y in children born full-term is associated with prenatal and postnatal dietary factors: a report from a population-based cohort study. Am J Clin Nutr.
115 Woltil HA, van Beusekom CM, Okken-Beukens M, et al. (1999). Development of low-birthweight infants at 19 months of age correlates with early intake and status of long-chain polyunsaturated fatty acids. Prostaglandins Leukotrienes & Essential Fatty Acids.
116 Woltil HA, van Beusekom CM, Schaafsma A, et al. (1998). Long-chain polyunsaturated fatty acid status and early growth of low birth weight infants. Eur J Pediatr.
117 Xiang M, Alfven G, Blennow M, et al. (2000). Long-chain polyunsaturated fatty acids in human milk and brain growth during early infancy. Acta Paediatr.