# Appendix G Strength of Evidence

Table G1 Strength of evidence for KQ1: maternal outcomes (gestational length, preterm birth, SGA/IUGR, low birth weight, birth weight, antenatal and/or postnatal depression)

Outcome | Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
Gestational length | n-3 FA supplementation | Healthy pregnant women | Moderate | RCT: 14 (original report); 14 Obs intake: 3 Obs biomarkers: 1 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: NA All: Consistent | Precise | Large heterogeneity in the meta-analysis | Original report: Mixed findings Meta-analysis of 12 RCTs in update: WMD 0.33 (95% CI 0.04, 0.62) weeks
Gestational length | DHA or DHA-rich fish oil | Healthy pregnant women | Moderate | RCT: 3 (original report); 11 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: Inconsistent | Precise | Large heterogeneity in the meta-analysis | Original report: Mixed findings Meta-analysis of 11 RCTs in update: WMD 0.34 (95% CI 0.02, 0.67) weeks
Gestational length | Fish oil or EPA+DHA | Healthy pregnant women | Low | RCT: 11 (original report); 2 Obs intake: 2 Obs biomarkers: 1 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: NA All: Consistent | Imprecise | A few studies excluded preterm infants | Original report: No effects No effects
Gestational length | DHA+AA | Healthy pregnant women | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | High | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Imprecise | Sparse | No effects
Gestational length | EPA+DHA vs. ALA | Healthy pregnant women | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Precise | Sparse | No differences between 5 differences doses of fish oil (EPA+DHA 0.1, 0.3, 0.7, 1.4 and 2.8 g/d) and ALA control
Gestational length | n-6/n-3 | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Gestational length | Other – total n-3 FA | Healthy pregnant women | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 1 (original report); 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Precise | Sparse | No associations
Preterm birth | DHA or DHA-rich fish oil | Healthy pregnant women | Low | RCT: 2 (original report); 5 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | Imprecise | No Obs | Meta-analysis of 7 RCTs: OR 0.87 (95% CI 0.66, 1.15)
Preterm birth | Fish oil or EPA+DHA | At risk pregnant women | Low | RCT: 8 (original report); 1 Obs intake: 1 Obs biomarkers: 1 | Moderate | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: Consistent | Imprecise | NA | Meta-analysis of 9 RCTs: 0.86 (95% CI 0.65, 1.15) Highest and lowest quartiles of maternal DHA+EPA intake: OR 1.1 (95% CI 0.7, 1.9) Erythrocyte DHA+EPA top 3 quartiles vs. lowest quartile: OR 1.41 (95% CI 0.97 – 2.05)
Preterm birth | DHA+AA | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Preterm birth | n-6/n-3 | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
SGA/IUGR | DHA or DHA-rich fish oil | At risk pregnant women | Insufficient | RCT: 2 Obs intake: Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | Imprecise | Sparse | No effects
SGA/IUGR | Fish oil or EPA+DHA | At risk pregnant women | Low | RCT: 3 (original report); 1 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: Consistent | Imprecise | NA | Meta-analysis of 4 RCTs: OR 1.00 (95% CI 0.70, 1.43) No association between quartiles of DHA+EPA intake and risk of having an SGA birth outcome
SGA/IUGR | DHA+AA | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
SGA/IUGR | n-6/n-3 | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
SGA/IUGR | Other – EPA or DHA | Healthy pregnant women | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Precise | Sparse | Lowest quintile of plasma EPA concentration (<0.33 mg/L) vs. middle quintile (0.46 -0.58 mg/L): AOR 2.09 (95% CI 1.32, 3.30) No associations for concentrations of plasma DHA
Low birth weight | DHA or DHA-rich fish oil | Healthy pregnant women | Low | RCT: 4 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | Imprecise | Moderate heterogeneity in the meta-analysis; | Meta-analysis of 4 RCTs: OR 0.72 (95% CI 0.43, 1.11)
Low birth weight | Fish oil or EPA+DHA | At risk pregnant women | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Precise | Sparse | No effects
Low birth weight | DHA+AA | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Low birth weight | n-6/n-3 | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Low birth weight | Other - EPA | Healthy pregnant women | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Precise | No RCT | 1st tertile of EPA intake vs. the highest tertile: AOR 2.75 (95% CI 1.26, 6.02); and 2nd tertile of EPA vs. the highest tertile: AOR 2.54, (95% CI 1.17. 5.50)
Birth weight | n-3 FA supplementation | Healthy pregnant women | Moderate | RCT: 14 (original report); 16 Obs intake: 6 Obs biomarkers: 4 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: NA All: Consistent | Precise | Moderate heterogeneity in the meta-analysis | Original report: Mixed findings Meta-analysis of 16 RCTs in update: WMD 74.8 (95% CI 12.4, 137.17) grams
Birth weight | DHA or DHA-rich fish oil | Healthy Pregnant women | Moderate | RCT: 2 (original report); 11 Obs intake: 0 Obs biomarkers: 3 | Low | RCT: Consistent Obs intake: Obs biomarkers: Consistent All: Consistent | Precise | Large heterogeneity in the meta-analysis | Original report: mixed findings Meta-analysis of 12 RCTs: WMD 90.12 (95% CI 2.62, 177.62) grams Higher maternal blood DHA concentrations were associated with higher birth weight.
Birth weight | Fish oil or EPA+DHA | Healthy Pregnant women | Low | RCT: 9 (original report); 5 Obs intake: 2 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: Inconsistent Obs biomarkers: NA All: Inconsistent | Precise | NA | Original report: mostly no effects Meta-analysis of 5 RCTs: WMD 37.89 (95% CI -19.53, 95.31) grams
Birth weight | DHA+AA | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Birth weight | n-6/n-3 | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Birth weight | Other - ALA | Healthy Pregnant women | Insufficient | RCT: 1 Obs intake: Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Imprecise | Sparse | Black current seed oil (ALA 0.42 g/d; SDA 0.09 g/d) vs. placebo: No effects
Birth weight | Other - total n-3 FA | Healthy Pregnant women | Insufficient | RCT: 0 Obs intake: 2 Obs biomarkers: 0 | Low | RCT: NA Obs intake: Consistent Obs biomarkers: NA All: NA | Precise | Sparse; No RCT | No associations
Antenatal and/or Postnatal Depression | DHA or DHA-rich fish oil (prenatal) | Pregnant woman | Low | RCT: 4 Obs intake: 0 Obs biomarkers: 3 | Moderate | RCTs: Consistent Obs intake: NA Obs biomarkers: Consistent All: Consistent | Imprecise | Outcome definitions were heterogeneous | Mostly no significant effects/associations on both antenatal and postnatal depression outcomes
Antenatal and/or Postnatal Depression | Fish oil or EPA+DHA (prenatal) | Pregnant woman | Insufficient | RCT: 1 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: Consistent | Imprecise | Outcome definitions were heterogeneous | No significant effects/associations on both antenatal and postnatal depression outcomes
Antenatal and/or Postnatal Depression | DHA+AA (prenatal) | Pregnant woman | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | High | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Imprecise | Sparse | No differences in median EPDS scores at either week 36 of pregnancy or 6 months postpartum
Antenatal and/or Postnatal Depression | n-6/n-3 (prenatal) | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Antenatal and/or Postnatal Depression | Other – total n-3 FA (prenatal) | Pregnant woman | Insufficient | RCT: 0 Obs intake: 2 Obs biomarkers: 0 | Low | RCT: NA Obs intake: Consistent Obs biomarkers: NA All: NA | Precise | No RCTs; Outcome definitions were heterogeneous | No associations and no significant dose-response relationship
Postnatal Depression | DHA or DHA-rich fish oil (postnatal) | Lactating women | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Imprecise | Sparse | No significant effects any of the time points (3 weeks, 2 months, 4 months, or 18 months postpartum)
Postnatal Depression | Fish oil or EPA+DHA (postnatal) | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Postnatal Depression | DHA+AA (postnatal) | No studies | Insufficient | RCT: Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Postnatal Depression | n-6/n-3 (postnatal) | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA
Postnatal Depression | Other – total n-3 FA (postnatal) | No studies | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | NA | NA | No data | NA

Table G2 Strength of evidence for KQ1: maternal outcomes (gestational hypertension/preeclampsia)

Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
DHA | Pregnant women not at risk for poor pregnancy outcomes | Low | RCT: 3 Obs intake: 0 Obs biomarkers: 0 | Cochrane 11,12,13/13 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | All interventions had very low levels EPA | RCT: OR 0.94[0.66, 1.34], I^2^=0% (n=2,818) Obs intake: NA Obs biomarkers: NA
DHA+EPA | Healthy pregnant women | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: | Newcastle-Ottawa Low RoB | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Only 1 cohort study | RCT: NA Obs intake: nonsignificant decrease in risk Obs biomarkers: NA
Fishoil | Pregnant women at risk for poor pregnancy outcomes | Moderate | RCT: 3 Obs intake: 1 Obs biomarkers: | Cochrane: 13/13 Newcastle-Ottawa: Low RoB | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | At-risk populations | RCT: OR 1.04 [0.76 , 1.42], I^2=^ 0% Obs intake: U-shaped association with risk Obs biomarkers: NA
DHA+AA | No studies | Insufficient | RCT: 0 Obs intake: NA Obs biomarkers: NA | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | NA | RCT: NA Obs intake: NA Obs biomarkers: NA
n-3 FA | Healthy pregnant women | Insufficient | RCT: 0 Obs intake:2 Obs biomarkers: 1 | Newcastle-Ottawa: Low RoB | RCT: NA Obs intake: Consistent Obs biomarkers: NA (1 study) All: NA | RCT: NA Obs intake: NA Obs biomarker: precise | NA | RCT: NA Obs intake: No association Obs biomarkers: inverse association

Table G3 Strength of evidence for KQ2: infant and child outcomes (growth patterns)

Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
DHA+EPA | Prenatal maternal intervention | Moderate | RCT: 6 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 3-9/13 | RCT: Mostly consistent Obs intake: NA Obs biomarkers: NA All: Mostly consistent | RCT: Precise Obs intake: NA Obs biomarker: NA | NA | RCT: No effect, pooled results for weight at 18 months 0.22 [-0.62, 0.19], length 0.01 [-0.52, 0.54], head circumf. -0.01 [-0.28,0.27]
DHA+AA | Prenatal + postnatal maternal intervention | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 1/13 (very high ROB) | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect
DHA+EPA | Prenatal + postnatal maternal intervention | Low | RCT: 4 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 2-10/13 | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: NA Obs intake: NA Obs biomarker: NA | NA | RCT: No effect
n-3 FAs | Prenatal + postnatal maternal intervention | Insufficient | RCT: 0 Obs intake: 2 Obs biomarkers: 0 | Observational only; fair quality | RCT: NA Obs intake: Inconsistent Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No RCTs | Obs intake: 1 study found no effect, 1 found neg. assoc. with n-3s and length at 1y
DHA+EPA | Postnatal maternal intervention | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 6/13 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: Greater BMI and head circumf. At 2.5 years in fish oil group
n-3 FAs | Postnatal maternal intervention | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Observational only; fair quality | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No RCTs | Obs intake: No effect
DHA+EPA | Prenatal maternal + preterm infant intervention | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Cochrane 7-9/13 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: Pos. assoc. with n-3s and length at 18 mo.
DHA+AA | Preterm infants | Low | RCT: 3 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 4-9/13 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: Inconsistent | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect, pooled results for weight at 4 months -0.01 [-0.48, 0.47, length -0.03 [-0.91, 0.85]; 1 study found lower fat mass and greater lean mass at 12 mo
DHA+AA+EPA | Preterm infants | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 4-9/13 | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect on weight, length, head circumf; 1 study found lower fat mass and greater lean mass at 12 mo
DHA+AA | Term infants | Low | RCT: 6 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 5-9/13 | RCT: Mostly consistent Obs intake: NA Obs biomarkers: NA All: Mostly consistent | RCT: NA Obs intake: NA Obs biomarker: NA | NA | RCT: No differences in overall weight, length, or head circumf. One study had higher rates of length gain. One had overall higher weight and stature for age percentiles from 2-6 years, but no differences in BMI or BMI-for-age.
Infant n-3 FA biomarkers | Term and preterm infants | Low | RCT: 0 Obs intake: 0 Obs biomarkers: 3 | Observational only; good quality | RCT: NA Obs intake: NA Obs biomarkers: Inconsistent All: Inconsistent | RCT: NA Obs intake: NA Obs biomarker: NA | NA | Obs biomarkers: Two studies found pos. assoc. with weight and length gain; one study found pos. assoc. with BMI at 7 yrs.

Table G4 Strength of evidence for KQ2: infant and child outcomes (neurological development)

Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
DHA | Preterm intervention | Low | RCT: 4 Obs intake: Obs biomarkers: 4 | Cochrane 9-13/13 NOS: fair-very good | RCT: Slightly inconsistent Obs intake: NA Obs biomarkers: Inconsistent All: Consistently inconsistent | RCT: NA Obs intake: NA Obs biomarker: NA | Outcome measures vary. 1 RCT included trace EPA | RCT: No differences for most outcome measures Obs intake: NA Obs biomarkers: Possible associations with some outcomes
DHA+EPA | Preterm intervention | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: Obs biomarkers:
Fish oil | Preterm intervention | Insufficient | RCT: 4 Obs intake: 0 Obs biomarkers: 1 | Cochrane 6-13/13 NOS: fair | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: No differences Obs intake: NA Obs biomarkers: NA
DHA+AA | Preterm intervention | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Obs biomarker: | No data | RCT: NA Obs intake: Obs biomarkers:
n-6/n-3 | Preterm intervention | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 1 | NOS fair-good | RCT: NA Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: NA Obs intake: NA Obs biomarker: NA | No RCT | RCT: NA Obs intake: No association Obs biomarkers: No association
n-3 FA | Preterm intervention | Insufficient | RCT: 0 Obs intake:2 Obs biomarkers: 5 | NOS fair-very good | RCT: NA Obs intake: Inconsistent Obs biomarkers: All: NA | RCT: NA Obs intake: Obs biomarker: | No RCT | RCT: NA Obs intake: 1 of 5 showed association for one outcome Obs biomarkers: NA
DHA | Pre and postnatal intervention | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 4/11 12/13 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Sparse (1 RCT reported in 2 publications) | RCT: Increase in mildly abnormal movements cf. placebo Obs intake: NA Obs biomarkers: NA All: NA
DHA+EPA | Pre and postnatal intervention | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA
Fish oil | Pre and postnatal intervention | | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA
DHA+AA | Pre and postnatal intervention | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 4/11 12/13 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | Sparse | RCT: Decrease in mildly abnormal movements cf. DHA alone and placebo Obs intake: NA Obs biomarkers: NA All: NA
n-6/n-3 | Pre and postnatal intervention | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 1 | Cochrane 4/11 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | No RCT | RCT: NA Obs intake:NA Obs biomarkers: No association
DHA | Breast Feeding Mothers | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 1 | Cochrane: 7/11 8/12 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No RCT | RCT: Inconsistent effects over time and among tests Obs intake: NA Obs biomarkers: No association
DHA+EPA | Breast Feeding Mothers | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Fishoil | Breast Feeding Mothers | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+AA | Breast Feeding Mothers | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
n-6/n- 3 | Breast Feeding Mothers | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs: NA Obs biomarkers: In All: | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA | Preterm infants | Insuffiient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake:NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+EPA | Preterm infants | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | 7357 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | Sparse DHA-enriched tuna oil | RCT: No differences Obs intake: NA Obs biomarkers: NA
Fish oil | Preterm infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+AA | Preterm infants | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 12/13 6/13 | RCT: Consistent Obs: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: | Sparse | RCT: Significantly higher PDI scores at 12, 18 months Obs intake: NA Obs biomarkers: NA
n-6/n-3 | Preterm infants | Insufficient | RCT: 0 Obs: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake:NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA | Term Infants | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: | Cochrane: 9/13 9/13 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | Sparse | RCT: Positive effects on brainstem maturation but mixed effects on gross motor control Obs intake: NA Obs biomarkers: NA
DHA+EPA | Term Infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Fish oil | Term Infants | Insufficient | RCT:1 Obs intake: 0 Obs biomarkers: 0 | 9/13 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: No effects on 3 indices Obs intake: NA Obs biomarkers: NA
DHA+AA | Term Infants | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Cochrane: 9/13 6/13 | RCT: NA Obs intake: In Obs biomarkers: NA All: NA | RCT: NA Obs intake: Obs biomarker: NA | 1 RCT in 3 publications | RCT: small but significant effect at 3 months not seen at 18 months or 9 years in one RCT; and no effects on PDI in the other RCT Obs intake: NA Obs biomarkers: NA
n-6/n-3 | Term Infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: Obs intake: NA Obs biomarker: NA | | RCT: No effect Obs intake: NA Obs biomarkers: NA

Table G5 Strength of evidence for KQ2: infant and child outcomes (visual function)

Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
DHA | Preterm intervention | Low | RCT: 4 Obs intake: 0 Obs biomarkers: 2 | Cochrane:10/13, 9/11, 7/11,13/13 | RCT: Consistent Obs intake: Inconsistent Obs biomarkers: Inconsistent All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | 2 RCTs included small amts. EPA; all used different outcome measures and FU times | RCT: no effect on visual acuity Obs intake: NA Obs biomarkers: Inconsistent associations
DHA+EPA | | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: Inconsistent Obs biomarkers: NA All: Inconsistent | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Fish oil | | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+AA | | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
n-6/n-3 | | insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA | Breast Feeding mothers | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 1 | Cochrane 8/12 | RCT: Inconsistent across time points Obs intake: Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: Improvement in one VEP outcome 4 and 8 months but no difference at 5 years Obs intake: NA Obs biomarkers: No association
DHA+EPA | Breast Feeding mothers | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Fish oil | Breast Feeding mothers | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 1 | Cochrane 12/12 | RCT: NA Obs intake: NA Obs biomarkers: NA All: divergence between RCT and biomarker results | RCT: NA Obs intake: NA; Obs. biomarker | Sparse data | RCT: no effect observed on visual acuity at 4 months Obs intake: NA Obs biomarkers: significant association of infant RBC DHA and visual acuity at 4 months
DHA+AA | Breast Feeding mothers | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
n-6/n-3 | Breast Feeding mothers | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: | NA | RCT: NA Obs: NA Obs biomarkers: NA All: | RCT: NA Obs intake: NA Obs biomarker: Precise | No data | RCT: NA Obs intake: NA Obs biomarkers: Unclear
Any n-3 FAs | Preterm infants VEP 4 months | Low | Pooled analysis of 4 RCTs (5 outcomes) | Study quality varied widely (Cochrane 6/11 and 4/11, jadad 3 and 5) | Inconsistent | Precise | Studies differed by intervention | WMD non-significant at 4 months followup WMD -0.06 (−0.12; 0.01)
Any n-3 FAs | Preterm infants VEP 6 months | Low | Pooled analysis of 4 RCTs (5 outcomes) | Study quality varied widely (Cochrane 6/11 and 4/11, jadad 3 and 5) | Inconsistent | Precise | Studies differed by intervention | WMD non-significant at 6 months followup WMD -0.04[ -0.09, 0.01
DHA | Preterm infants | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Cochrane 10/13, 8/11 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | Sparse One study included small amount EPA | RCT: No differences at 2, 4 months CA in one study Obs intake: NA Obs biomarkers: NA
DHA+EPA | Preterm infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Fishoil | Preterm infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+AA | Preterm infants | Low | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Cochrane 7/11 | RCT: NA Obs: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: Unclear | Sparse | RCT: 1 new study and 5 from original report show no consistent effect Obs intake: NA Obs biomarkers: NA
n-6/n-3 | Preterm infants | Insufficient | RCT: 0 Obs: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Any n-3 FA | Term infants 2 month followup Behavioral | Low | RCT:6 Obs: 0 Obs biomarkers: 0 | Jadad 3.8 | Inconsistent | Precise | Small effect size | Significant effect on BM 2 months WMD 0.07 [0.00, 0.14] six RCTs
Any n-3 FA | Term infants 2 month followup VEP | Low | RCT:6 Obs: 0 Obs biomarkers: 0 | Jadad 4.2 Cochrane 9/13 | Inconsistent | Precise | Medium heterogeneity | Nonsignificant effect on VEP at 2 months WMD 0.07[-0.03, 0.17], six RCTs
Any n-3 FA | Term infants 4 month followup Behavioral | Low | RCT:6 Obs: 0 Obs biomarkers: 0 | Jadad 3.8 | Inconsistent | Precise | No new studies | Non-significant effect on BM at 4 months WMD -0.05 [-0.08, -0.01], six RCTs
Any n-3 FA | Term infants 4 month followup VEP | Moderate | RCT:8 Obs: 0 Obs biomarkers: 0 | Jadad 3.8 Cochrane 7-9/13 | Inconsistent | Precise | | Significant effect of n-3 FAs on VEP at 4 months WMD -0.10 (-0.14, -0.07), eight RCTs
Any n-3 FA | Term infants 12 month followup Behavioral | Low | RCT:6 Obs: 0 Obs biomarkers: 0 | Jadad 3.8 | Inconsistent | Precise | | Non-significant effect of n-3 FA on BM at 12 months WMD -0.10 (-0.14, -0.07) six RCTs
Any n-3 FA | Term infants 12 month followup VEP | Moderate | RCT:8 Obs: 0 Obs biomarkers: 0 | Jadad 4.0 Cochrane 7-9/13 | Consistent | Precise | | Significant effect of n-3 FA on VEP at 12 months WMD -0.14 (-0.17, -0.12) 8 RCTs
DHA | Term infants | Low | RCT: 1 Obs intake: 0 Obs biomarkers: 1 | Cochrane 12/13 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | Sparse | RCT: 1 new study and 2 RCTs from original report suggest possible lasting benefit but inconsistent Obs intake: NA Obs biomarkers: NA
DHA+EPA | Term infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Fishoil | Term infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+AA | Term infants 2 months followup Behavioral | Low | RCT: 4 Obs intake: 0 Obs biomarkers: 0 | Jadad 3.8 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | No new studies | No significant effect on BM at 2 months Obs intake: NA Obs biomarkers: NA WMD -0.07 (-0.19, 0.04) six RCTs
DHA+AA | Term infants 2 months followup VEP | Low | RCT: 6 | Jadad 4.2 Cochrane 9/13 | Inconsistent | Precise | One new study | No significant effect on VEP at 2 months WMD -0.06 (−0.22; 0.10)
DHA+AA | Term infants 4 months followup Behavioral | Low | RCT: 6 | Jadad 3.8 | Inconsistent | Precise | No new studies | No significant effect on BM at 4 months WMD 0.04 (0.02, 0.10)
DHA+AA | Term infants 4 months followup VEP | Low | RCT: 5 | Jadad 4.3 Cochrane 7-9/13 | Inconsistent | Precise | Two new studies | Significant effect on VEP at 4 months WMD -0.10 [-0.14, -0.07
DHA+AA | Term infants 12 months followup Behavioral | Moderate | RCT: 4 | Jadad 3.75 | Consistent | Precise | No new studies | No significant effect on BM at 12 months WMD 0.01 (-0.01, 0.02)
DHA+AA | Term infants 12 months followup VEP | Low | RCT: 6 | Jadad 4.0 7-9/13 | Inconsistent | Precise | 2 new studies | Significant effect on VEP at 12 months WMD -0.14 (-0.17, -0.12)
n-6/n-3 | Term infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA

Table G6 Strength of evidence for KQ2: infant and child outcomes (cognitive)

Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
Any n-3 FA | Preterm infants | Moderate | RCTs: 7 | Medium risk of bias | High | Imprecise | Heterogeneous interventions | Significant increase in cognitive development (MDI scores) WMD 2.24; (95% CI 0.05, 4.43)
DHA | Preterm Infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No studies | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+EPA | Preterm Infants | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Low risk of bias | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarkers: NA
DHA+AA | Preterm Infants | Low | RCT: at 2 Obs intake: 0 Obs biomarkers: 0 | 1 RCT: Unclear allocation concealment and sequence 1 RCT: Attrition bias | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: Mixed Obs intake: NA Obs biomarkers: NA
DHA+EPA +AA | Preterm Infants | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | 1 RCT: High Risk of Bias 1 RCT: Attrition bias | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: Mixed Obs intake: NA Obs biomarkers: NA
DHA | Full Term Infants | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Low risk of bias | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarkers: NA
DHA+EPA | Full Term Infants | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | 1 RCT: Low risk of bias 1 RCT: High risk of bias | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: Unclear Obs biomarker: NA | Sparse | RCT: No effect Obs intake: Lower risk Obs biomarkers: NA
DHA+AA | Full Term Infants | Low | RCT: 3 Obs intake: 0 Obs biomarkers: 0 | Low risk of bias | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse, heterogeneous studies | No significant effect on MDI scores at 18-24 months of age WMD 0.75, 95% CI -9.29, 10.79 Obs intake: NA Obs biomarkers: NA
DHA | Pregnant women | Low for no effect | RCT: 1 Obs intake: 2 Obs biomarkers: 4 | Low risk of bias | RCT: NA Obs intake: Consistent Obs biomarkers: Consistent All: Consistent | RCT: Precise Obs intake: Precise Obs biomarkers: Imprecise | RCT Outcome was Neonatal Behavior Assessment at age 14 days | RCT: Positive effect Obs intake: No effect Obs biomarkers: No effect
DHA+EPA | Pregnant women | Moderate for no effect | RCT: 5 Obs intake: 2 Obs biomarkers 2: | 3 RCTs: Low ROB 2 RCTs: High ROB Observational: Low ROB | RCT: Consistent Obs intake: Consistent Obs biomarkers: Consistent All: Consistent | RCT: Precise Obs intake: Precise Obs biomarkers: Precise | Observational report results for DHA and EPA levels separately | RCT: No effect Obs intake: No effect of EPA: Obs biomarkers: No effect
DHA+AA | Pregnant women | Moderate for no effect | RCT: 1 Obs intake: 2 Obs biomarkers: 4 | RCT: High ROB Observational: Low ROB | RCT: NA Obs: Consistent Obs biomarkers: Inconsistent All: Consistent with one exception | RCT: Precise Obs intake: Precise Obs biomarkers: Imprecise | Observational report results for DHA and AA levels separately | RCT: No effect Obs intake: No effect Obs biomarkers: effect in one study
n-6/n-3 | Pregnant women | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Low ROB | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Imprecise Obs: biomarkers: NA | Effect only in offspring never breastfed | RCT: NA Obs intake: Positive effect Obs biomarkers: NA
Other: ALA | Pregnant women | Insufficient | RCT: 0 Obs intake: 2 Obs biomarkers: 1 | Low ROB | RCT: NA Obs intake: Consistent Obs biomarkers: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarkers: Precise | No RCTs | RCT: NA Obs intake: No effect Obs biomarkers: No effect
DHA | Breast feeding women | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT:NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | No studies | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+EPA | Breast feeding women | Low for no effect | RCT: 4 Obs intake: 0 Obs biomarkers: 0 | 1 RCT: Low ROB 2 RCTs: Moderate ROB 1 RCT: High ROB | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: Obs biomarkers: | | RCT: No effect Obs intake: Obs biomarkers:
DHA+AA | Breast feeding women | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: | Moderate ROB | RCT: NA Obs intake: NA Obs biomarkers: NA All: A | RCT: NA Obs intake: NA Obs biomarker: Precise | No RCTs Observational report results for DHA and AA levels separately | RCT: NA Obs intake: NA Obs biomarkers: No effect

Table G7 Strength of evidence for KQ2: infant and child outcomes (autism spectrum disorders)

Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
DHA | Preterm Infants (1 RCT) Pregnant women (1 RCT, 1 Obs) | Low for no effect | RCT: 2 Obs intake: 1 Obs biomarkers: 0 | 2 RCTs: Low ROB Obs: Low ROB | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Obs study authors advise that the results should be interpreted with caution, given the small number of cases | RCT: No association Obs intake: women with the highest quartile of total PUFA intake were at lower risk of having a child with ASD than women in the lowest quartile Obs biomarkers: NA

Table G8 Strength of evidence for KQ2: infant and child outcomes (attention deficit hyperactivity disorder)

Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
DHA | Preterm Infants (2 RCTs) Pregnant women (1 RCT) | Low for no effect | RCT: 3 Obs intake: 0 Obs biomarkers: 0 | 2 RCTs: Low ROB 1 RCT: High ROB | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | The RCT reporting ADHD diagnosis at 10 year follow-up had over 50% attrition | RCT: No association with attention outcomes or diagnosis of ADHD Obs intake: NA Obs biomarkers: NA

Table G9 Strength of evidence for KQ2: infant and child outcomes (atopic dermatitis, allergies, and respiratory illness)

Outcome | Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
Atopic Dermatitis | DHA | Prenatal + Postnatal intervention-preterm and term infants | Low | RCT:1 Obs intake: 2 Obs biomarkers: 1 | Cochrane: 10/11 NOS: fair | RCT: NA Obs intake: Consistent Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | RCT compared high DHA to standard DHA diet | RCT: No difference in risk Obs intake: No significant association Obs biomarkers: low risk
Atopic Dermatitis | DHA+EPA | Prenatal intervention-preterm and term infants | Low | RCT: 4(2 follow-up) Obs intake: 6 Obs biomarkers: NA | Cochrane: 9/12,5/12, 12/13, ,12/13 NOS: poor-fair | RCT: Inconsistent Obs intake: Consistent Obs biomarkers: All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | | RCT: one study reported a significant risk reduction, remaining found no significant difference Obs intake: No association Obs biomarkers: NA
Atopic Dermatitis | DHA+EPA | Postnatal intervention-preterm and term infants | Insufficient | RCT: 1 Obs intake: NA Obs biomarkers: NA | Cochrane: 9/13 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: No significant difference Obs intake: NA Obs biomarkers: NA
Atopic Dermatitis | Fish oil | Prenatal +Postnatal intervention | Low | RCT: 3 (+2 follow-up) Obs intake: 0 Obs biomarkers: 0 | Cochrane: 9/12,10/13,10/13 | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: | | RCT: No significant difference Obs intake: NA Obs biomarkers: NA
Atopic Dermatitis | n-3 FA | Prenatal +Postnatal intervention | Low | RCT: 1 (+2 follow-up) Obs intake: 7 Obs biomarkers:3 | RCT:10-11/13 NOS: poor-good | RCT: Consistent Obs intake: Inconsistent Obs biomarkers: Consistent All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | | RCT: No significant difference Obs intake: One of the studies found reduced risk, others found no significant association Obs biomarkers: No association
Atopic Dermatitis | n-6/n-3 | Prenatal +Postnatal intervention-Term infants | Low | RCT: 0 Obs intake: 5 Obs biomarkers: 3 | NOS: poor-good | RCT: NA Obs intake: Consistent Obs biomarkers: Inconsistent All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | | RCT: NA Obs intake: No association Obs biomarkers: One of the studies found reduced risk, others found no significant association
Atopic Dermatitis | ALA | Prenatal +Postnatal intervention-Term infants | Low | RCT: 1 Obs intake:1 Obs biomarkers:2 | Cochrane: 11/12 NOS: fair-good | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: Significant risk reduction at 12 month follow-up Obs intake: No significant association Obs biomarkers: No significant association
Allergies | DHA | Prenatal + Postnatal intervention-preterm and term infants | Low | RCT: 1 Obs intake: 2 Obs biomarkers: 3 | Cochrane: 10/11 NOS: fair-good | RCT: NA Obs intake: Consistent Obs biomarkers: Inconsistent All: NA | RCT: NA Obs intake: Obs biomarker: NA | Sparse | RCT: No significant difference Obs intake: No significant association Obs biomarkers: One of the studies reported low risk, others found no significant association
Allergies | DHA+EPA | Prenatal intervention | Low | RCT: 3 (+2 follow-up) Obs intake: 1 Obs biomarkers: 0 | Cochrane: 12/13,9/12,11-12/13, NOS: fair | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | | RCT: Non-significant effect on allergy risk at 12 months OR 0.54 (95% CI 0.05, 6.2) (3 RCTs) Obs intake: no significant association Obs biomarkers: NA
Allergies | DHA+EPA | Postnatal intervention | Insufficient | RCT: 1 Obs intake: NA Obs biomarkers: NA | Cochrane: 9/13 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: No significant association Obs intake: NA Obs biomarkers: NA
Allergies | Fish oil | Prenatal + Postnatal intervention-preterm and term infants | Low | RCT: 3 (+2 follow-up) Obs intake: NA Obs biomarkers: NA | Cochrane: 9/13, 10/13, 9/12 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT:NA Obs intake: NA Obs biomarker: NA | | RCT: No significant association Obs intake: NA Obs biomarkers: NA
Allergies | n-3 FA | Prenatal + Postnatal intervention-preterm and term infants | Low | RCT: 0 Obs intake:4 Obs biomarkers: 4 | NOS: poor-good | RCT: NA Obs intake: Inconsistent Obs biomarkers: Consistent All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: one study found reduced risk, others found no significant association Obs biomarkers: No association
Allergies | n-6/n-3 | Prenatal + Postnatal intervention-preterm and term infants | Low | RCT: 0 Obs intake: 2 Obs biomarkers: 4 | NOS: poor-good | RCT: NA Obs intake: Inconsistent Obs biomarkers: Consistent All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | | RCT: NA Obs intake: one study found a significant association, the other found no significant association Obs biomarkers: No significant association
Allergies | Other-ALA | Prenatal + Postnatal intervention-preterm and term infants | Low | RCT: 1 Obs intake:2 Obs biomarkers:2 | Cochrane: 11/12 NOS: fair-good | RCT: NA Obs intake: Consistent Obs biomarkers: Consistent All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | A study reported positive association with sensitization in infants with no maternal history of allergy | RCT: No significant difference Obs intake: No significant association Obs biomarkers: No significant association
Respiratory Illness: Wheeze | DHA | Prenatal + Postnatal intervention-preterm and term infants | Low | RCT: 3 Obs intake: 5 Obs biomarkers:4 | Cochrane: 11/13, 10/13 NOS: poor-good | RCT: Inconsistent Obs intake: Inconsistent Obs biomarkers: Inconsistent All: Inconsistent | RCT:NA Obs intake: NA Obs biomarkers: NA | | RCT: no significant effect on risk for wheeze at 12 months OR 0.95 (95% CI 0.77,1.16) (3 RCTs) Obs intake: one study found a significant risk reduction, others found no significant association Obs biomarkers: one study reported a significant risk reduction, others found no significant association.
Respiratory Illness: Wheeze | DHA+EPA | Prenatal intervention | Low | RCT: 2 Obs intake: 1 Obs biomarkers: NA | Cochrane: 5/12,9/12 NOS: poor | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | | RCT: no significant difference Obs intake: Reduced risk Obs biomarkers: NA
Respiratory Illness: Wheeze | Fish oil | Prenatal + Postnatal intervention | Low | RCT: 3 (+3 follow-up) Obs intake: 0 Obs biomarkers: 0 | Cochrane: 10/13,9/13 9/12 | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | | RCT: No significant difference Obs intake: NA Obs biomarkers: NA
Respiratory Illness: Wheeze | DHA+AA | | | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | | RCT: NA Obs: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Respiratory Illness: Wheeze | n-6/n-3 | Prenatal + Postnatal intervention | Low | RCT: 0 Obs intake: 2 Obs biomarkers:3 | NOS: poor- fair | RCT: NA Obs intake: Consistent Obs biomarkers: Consistent All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | | RCT: NA Obs intake: No significant association Obs biomarkers: No significant association
Respiratory Illness: Wheeze | Total n-3 FA | Prenatal + Postnatal intervention | Low | RCT: 2 Obs intake: 3 Obs biomarkers: 4 | Cochrane: 10/13, 5/12 NOS: poor-good | RCT: Inconsistent Obs intake: Consistent Obs biomarkers: Inconsistent All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | One of the RCTs reports increased prevalence of wheeze at 8yr follow up. | RCT: One study reported significant risk reduction while the other found no significant difference Obs intake: No significant association Obs biomarkers: 2 studies found reduced risk, the other two found no significant association
Respiratory Illness: Asthma | DHA | Prenatal + Postnatal intervention | Low | RCT: 3 (+3 follow-up) Obs intake:2 Obs biomarkers: 1 | Cochrane: 10/13,9/13,10/13 NOS: fair-good | RCT: Consistent Obs intake: Inconsistent Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarkers: NA | | RCT: non-significant summary effect Obs intake: one study reported a significant association risk, other non-significant Obs biomarkers: No significant association
Respiratory Illness: Asthma | DHA+EPA | Prenatal intervention | Low | RCT: 4 Obs intake: NA Obs biomarkers: NA | Cochrane: 12/13,9/12,11/13,12/13 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | | RCT: non-significant difference Obs intake: NA Obs biomarkers: NA
Respiratory Illness: Asthma | Fish oil | Prenatal + Postnatal intervention | Low | RCT: 4 (+ 3 follow-up) Obs intake: 0 Obs biomarkers: 0 | Cochrane: 10/13,9/13,12/13, 9/12 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | | RCT: No significant difference Obs intake: NA Obs biomarkers: NA
Respiratory Illness: Asthma | DHA+AA | | | RCT: Obs intake: Obs biomarkers: | | RCT: Obs intake: Obs biomarkers: All: | RCT: Obs intake: Obs biomarker: | No data | RCT: Obs intake: Obs biomarkers:
Respiratory Illness: Asthma | n-6/n-3 | Prenatal + Postnatal intervention | Low | RCT: 0 Obs intake: 2 Obs biomarkers:2 | NOS: fair-good | RCT: NA Obs intake: Inconsistent Obs biomarkers: Consistent All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | | RCT: NA Obs intake: One study reported significant risk reduction while the other found no significant association Obs biomarkers: No association

Table G10 Strength of evidence for KQ2: infant and child outcomes (adverse events)

Intervention/exposure | Population | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
DHA | Pregnant women | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Fair McH | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | NA | RCT: No effect Obs intake: NA Obs biomarkers: NA
DHA+EPA | Pregnant women | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Mcharm 4/6 | RCT: NA Obs intake: NA Obs biomarkers: NA | RCT: NA Obs intake: NA Obs biomarker: NA | EPA/DHA>1 | RCT: ↑risk GI AEs Obs intake: Obs biomarkers:
Fishoil | Pregnant women | Insufficient | RCT: 0 Obs intake: Obs biomarkers: | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+AA | Pregnant women | Low | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Good-fair McH | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA | RCT: NA Obs intake: NA Obs biomarker: NA | Sparse | RCT: Unclear risk for GI AEs No SAEs Obs intake: Obs biomarkers:
n-6/n-3 | Pregnant women | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: Obs intake: Obs biomarkers | RCT: NA Obs intake: Obs biomarker: | Sparse | RCT: NA Obs intake: NA Obs biomarkers: NA
No studies | Breast Feeding women: maternal outcomes | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers
DHA | Breastfed term infants | Low | RCT: 2 Obs intake: 0 Obs biomarkers: | Good McH | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Obs biomarkers: NA | Sparse | RCT: No difference in AEs or lower AEs Obs intake: NA Obs biomarkers: NA
DHA+EPA | Breastfed term infants | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | McHarm 4/6 | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Fishoil | Breastfed term infants | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 1 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: Unclear | Sparse | RCT: NA Obs intake: NA Obs biomarkers: Lower risk
DHA+AA | Breastfed term infants | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: | Mcharm 4/5 | RCT: NA Obs: NA Obs biomarkers: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | Sparse, no obs | RCT: No differences in AEs Obs intake: NA Obs biomarkers:
n-6/n-3 | Breastfed term infants | Insufficient | RCT: 0 Obs: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA | Preterm infants formula fed | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 1 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: Imprecise | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+EPA | Preterm infants formula fed | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: NA Obs intake: Imprecise Obs biomarkers: Imprecise | No data | RCT: NA Obs intake: No association Obs biomarkers:
Fishoil | Preterm infants formula fed | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All:NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+AA | Preterm infants formula fed | Insufficient | RCT: 4 Obs intake: 0 Obs biomarkers: 0 | Mcharm 1,2,4/5; 3/6 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No obs; Risks associated with prematurity reported as AEs | RCT: No net effect on AEs Obs intake: Obs biomarkers: NA
n-6/n-3 | Preterm infants formula fed | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA | Term infants formula fed | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+EPA | Term infants formula fed | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Fishoil | Term infants formula fed | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
DHA+AA | Term infants formula fed | Moderate | RCT: 5 Obs intake: 0 Obs biomarkers: 0 | Mcharms 0, 2, 3, 4/5; 3/6 | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No obs. | RCT: No difference or fewer AEs in n-3 groups; no SAEs Obs intake: NA Obs biomarkers: NA
n-6/n-3 | Term infants formula fed | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA