# Appendix F Quality of Included Studies

Table F1 Quality assessment of randomized controlled trials

Author, year | Allocation Sequence Generated Adequately | Allocation Treatment Adequately Concealed | Participants Adequately Blinded | Outcome Assessors Blinded | Outcome Assessor Blinding is Different for Different Outcomes | Incomplete outcome data (Attrition bias) due to amount, nature or handling of incomplete outcome data | Attrition risk of bias is different for different outcomes or different time points | Selective Outcome Reporting | Intention-to-treat | Group Similarity at Baseline (general) | Group Similarity at Baseline (Omega-3) | Incomplete Compliance with Interventions Across Groups | Additional bias
Agostoni C, et al, 2009^139^ | Low risk | Low risk | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | No | Low risk | Unclear | Low risk | No
Almaas, et al., 2015^126^ | Low risk | Low risk | Low risk | Low risk | Not applicable | Low risk | High risk | No | No | Low risk | Low risk | Unclear | No
Atwell K, et al, 2013^119^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Low risk | No
Bergmann et al., 2012 ^52^ | Unclear | Unclear | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | No | Low risk | Unclear | Low risk | No
Birch EE, et al, 2010^121^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Unclear | Yes | Low risk | Unclear | Unclear | No
Birch EE, et al, 2005^111^ | Low risk | Low risk | Low risk | Unclear | Unclear | Low risk | High risk | No | Unclear | Low risk | Unclear | Unclear | No
Birch EE, et al, 2007^146^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | No | Unclear | Unclear | Low risk | No
Bouwstra H, et al, 2005^63^ | Low risk | Low risk | Low risk | Low risk | Unclear | Low risk | Low risk | No | No | Low risk | Unclear | Unclear | No
Bouwstra H, et al, 2003^62^ | Low risk | Low risk | Low risk | Low risk | Unclear | Low risk | Low risk | No | No | Low risk | Unclear | Unclear | No
Brew B, et al., 2015^165^ | Unclear | Low risk | Low risk | Low risk | Low risk | High risk | Unclear | Unclear | Yes | Low risk | Unclear | Low risk | Yes
Campoy C, et al, 2011^141^ | Low risk | Unclear | Low risk | Low risk | Not applicable | High risk | Not applicable | No | No | Low risk | Low risk | Unclear | No
Carlson SE, et al, 2013^31^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Carlson SE, et al, 1996^160^ | Low risk | Low risk | Low risk | Low risk | Not applicable | High risk | High risk | No | No | Low risk | Unclear | Unclear | No
Cheatham CL, et al, 2011^129^ | Unclear | Unclear | Low risk | Low risk | Low risk | High risk | Not applicable | Yes | No | Low risk | Low risk | Low risk | No
Clandinin MT, et al, 2005^108^ | Low risk | Low risk | Low risk | Low risk | Unclear | High risk | High risk | No | No | High risk | Unclear | Unclear | No
Collins CT, et al, 2015^120^ | Low risk | Low risk | Unclear | Low risk | Not applicable | Low risk | Not applicable | No | Unclear | Low risk | Low risk | Unclear | No
Collins CT, et al, 2011^105^ | Low risk | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Colombo J, et al, 2013^124^ | Unclear | Unclear | Low risk | Low risk | Low risk | Low risk | Unclear | No | Unclear | Unclear | Unclear | Unclear | No
Courville AB, et al, 2011^38^ | Unclear | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Currie LM, et al, 2015^115^ | Unclear | Unclear | Low risk | Low risk | Not applicable | High risk | Not applicable | No | No | Low risk | Unclear | Low risk | No
de Jong C, et al, 2012^65^ | Low risk | Low risk | Low risk | Low risk | Not applicable | Low risk | Not applicable | Yes | No | Low risk | Unclear | Unclear | Yes
de Jong C, et al, 2010^64^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | No | Low risk | Unclear | Unclear | No
Doornbos B, et al, 2009^90^ | Unclear | Unclear | Unclear | Unclear | Unclear | High risk | High risk | No | No | Low risk | High risk | Low risk | No
Drover JR, et al, 2012^123^ | Low risk | Low risk | Low risk | Low risk | Not applicable | High risk | Not applicable | No | No | Unclear | Unclear | Unclear | No
Drover JR, et al, 2011^122^ | Low risk | Low risk | Low risk | Low risk | Not applicable | Low risk | High risk | No | No | Low risk | Unclear | Unclear | No
Dunstan JA, et al, 2003^50^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | No | Low risk | Unclear | Unclear | No
Dunstan JA, et al, 2008^44^ | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | No | No | Low risk | Unclear | Unclear | Yes
D'Vaz N, et al, 2012^142^ | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | No | Yes | Unclear | Low risk | Low risk | No
Escamilla-Nunez MC, et al, 2014^59^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | No | Low risk | Low risk | Unclear | No
Escolano-Margarit MV, et al, 2011^130^ | Unclear | Unclear | Low risk | Low risk | Not applicable | High risk | Not applicable | No | No | Low risk | Low risk | Low risk | No
Fang PC, et al, 2005^137^ | Unclear | Unclear | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | No | Low risk | Unclear | Unclear | No
Field CJ, et al, 2008^112^ | Unclear | Unclear | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | Yes | Low risk | Low risk | Low risk | No
Fleddermann M, et al, 2014^113^ | Low risk | Low risk | Low risk | Low risk | Unclear | High risk | Low risk | No | Yes | Low risk | Unclear | Unclear | No
Furuhjelm C, et al, 2011^172^ | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | Unclear | No | No | Low risk | Low risk | Low risk | No
Furuhjelm C, et al, 2009^173^ | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | Unclear | No | Yes | Low risk | Low risk | Low risk | No
Gonzalez-Casanova I, et al, 2015^60^ | Unclear | Unclear | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | No | Low risk | Unclear | Low risk | No
Goor SA, et al, 2011^66^ | Unclear | Unclear | Unclear | Unclear | Unclear | High risk | Unclear | No | No | Low risk | Unclear | Unclear | No
Groh-Wargo S, et al, 2005^106^ | Low risk | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | High risk | Low risk | Low risk | No
Gustafson KM, et al, 2013^74^ | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | High risk | No | Yes | Low risk | Low risk | Low risk | No
Harper M, et al, 2010^29^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Hauner H, et al, 2012^37^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Helland IB, et al, 2008^76^ | Unclear | Unclear | Low risk | Low risk | Unclear | High risk | Unclear | No | No | High risk | Unclear | Unclear | Yes
Henriksen C, et al, 2008^107^ | Low risk | Low risk | Low risk | Low risk | Not applicable | High risk | High risk | No | No | Low risk | Unclear | Unclear | No
Hoffman D, et al, 2008^114^ | Low risk | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Imhoff-Kunsch B, et al, 2011^58^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Low risk | No
Innis SM, et al, 2008^145^ | Low risk | Low risk | Low risk | Low risk | Not applicable | Unclear | Not applicable | No | Unclear | High risk | Low risk | Unclear | Yes
Isaacs EB, et al, 2011^99^ | Low risk | Low risk | Low risk | Low risk | Not applicable | High risk | Not applicable | No | No | Unclear | Unclear | Unclear | Yes
Jensen CL, et al, 2010^135^ | Unclear | Unclear | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | No | Low risk | Unclear | Unclear | No
Jensen CL, et al, 2005^136^ | Low risk | Unclear | Low risk | Low risk | Not applicable | Low risk | High risk | No | No | Low risk | Unclear | Low risk | No
Judge MP, et al, 2014^91^ | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | Not applicable | No | No | Low risk | Unclear | Unclear | No
Judge MP, et al, 2012^40^ | Low risk | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Judge MP, et al, 2007^39^ | Unclear | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Knudsen VK, et al, 2006^45^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Lagemaat M, et al, 2011^109^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Unclear | No
Lauritzen L, et al, 2005^102^ | Unclear | Unclear | Low risk | High risk | Low risk | High risk | Low risk | No | No | Low risk | Low risk | Low risk | No
Lauritzen L, et al, 2004^127^ | Low risk | Low risk | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | Yes | Low risk | Low risk | Low risk | No
Lauritzen L, et al, 2005^128^ | Unclear | Unclear | Low risk | Low risk | Not applicable | Low risk | Not applicable | Yes | No | Low risk | Unclear | Low risk | No
Linnamaa P, et al, 2010^79^ | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Llorente AM, et al, 2003^98^ | Low risk | Unclear | Low risk | Low risk | Not applicable | High risk | High risk | No | No | Low risk | Low risk | Low risk | No
Lucia Bergmann R, et al, 2007^41^ | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | Low risk | Yes | Yes | Low risk | Low risk | Unclear | No
Makrides M, et al, 2009^116^ | Low risk | Unclear | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | Yes | Low risk | Unclear | Low risk | No
Makrides M, et al, 2010^35^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Makrides M, et al, 2014^57^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Low risk | No
Malcolm CA, et al, 2003^100^ | Unclear | Unclear | Low risk | Low risk | Low risk | High risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Manley BJ, et al, 2011^118^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Low risk | No
Marks GB, et al, 2006^168^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | No | Low risk | Unclear | Unclear | No
Meldrum SJ, et al, 2015^56^ | Unclear | Unclear | Low risk | Low risk | Low risk | High risk | High risk | Unclear | Yes | Low risk | Unclear | Unclear | No
Meldrum SJ, et al, 2012^140^ | Low risk | Low risk | Low risk | Low risk | Not applicable | High risk | Not applicable | No | No | High risk | Low risk | High risk | No
Mihrshahi S, et al, 2003^166^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | No | Low risk | Unclear | Unclear | No
Miles EA, et al, 2011^78^ | Low risk | High risk | High risk | Low risk | Unclear | Low risk | Unclear | No | No | Low risk | Low risk | Low risk | No
Min Y, et al, 2014^43^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Mozurkewich EL, et al, 2013^42^ | Low risk | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Mulder KA, et al, 2014^75^ | Low risk | Low risk | Low risk | Low risk | Not applicable | High risk | Low risk | No | No | High risk | Low risk | Unclear | No
Noakes PS, et al, 2012^88^ | Low risk | Unclear | High risk | Low risk | Low risk | High risk | Not applicable | No | No | Low risk | Unclear | Unclear | No
Olsen SF, et al, 2008^187^ | Low risk | Low risk | High risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Palmer DJ, et al, 2012^54^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Low risk | No
Palmer DJ, et al, 2013^56^ | Low risk | Low risk | Low risk | Low risk | Unclear | Low risk | Low risk | No | Yes | Low risk | Low risk | High risk | No
Peat JK, et al, 2004^167^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Unclear | No
Pietrantoni E, et al, 2014^30^ | Unclear | Unclear | Unclear | Unclear | Not applicable | Low risk | Not applicable | No | Yes | Low risk | Low risk | High risk | No
Ramakrishnan U, et al, 2010^32^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Low risk | Low risk | No
Ramakrishnan U, et al, 2015^61^ | Low risk | Low risk | Low risk | Low risk | High risk | Unclear | Not applicable | Yes | Yes | Low risk | Unclear | Low risk | No
Sala-Vila A, et al, 2004^110^ | High risk | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Low risk | No
Smithers LG, et al, 2010^117^ | Low risk | Low risk | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | Unclear | Low risk | Unclear | Unclear | No
Smithers LG, et al, 2011^53^ | Low risk | Low risk | Low risk | Low risk | Not applicable | Low risk | Not applicable | No | Yes | Low risk | Unclear | Unclear | No
Smithers LG, et al, 2008^104^ | Low risk | Low risk | Low risk | Unclear | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Unclear | No
Stein AD, et al, 2011^34^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Low risk | No
Stein AD, et al, 2012^33^ | Low risk | Low risk | Low risk | Low risk | Low risk | High risk | High risk | No | Yes | Low risk | Low risk | Low risk | No
Toelle BG, et al, 2010^169^ | Low risk | Low risk | Low risk | Low risk | Low risk | Low risk | Not applicable | No | No | Low risk | Unclear | Unclear | No
Tofail F, et al, 2006^77^ | Unclear | Unclear | Low risk | Low risk | Unclear | High risk | Not applicable | No | Unclear | High risk | Unclear | Low risk | No
Unay B, et al, 2004^138^ | Low risk | Low risk | Low risk | Unclear | Low risk | Low risk | Low risk | No | No | Low risk | Unclear | Unclear | No
van Goor SA, et al, 2010^36^ | Unclear | Unclear | Low risk | Unclear | Not applicable | High risk | Not applicable | Yes | No | Low risk | Unclear | Unclear | No
Werkman SH, et al, 1996^154^ | Low risk | Low risk | Unclear | Low risk | Low risk | Low risk | Not applicable | Yes | No | Low risk | Unclear | Unclear | No
Westerberg AneC, et al, 2011^125^ | Low risk | Low risk | Low risk | Low risk | Not applicable | High risk | Not applicable | Yes | Unclear | Low risk | Low risk | Unclear | No
Willatts P, et al, 2013^170^ | Low risk | Low risk | Low risk | Low risk | Not applicable | High risk | Not applicable | Unclear | No | Low risk | Unclear | Unclear | Yes
Zhou SJ, et al, 2012^55^ | Low risk | Unclear | Low risk | Low risk | Low risk | Low risk | Low risk | No | Yes | Low risk | Unclear | Low risk | No

Table F2 Quality assessment of cohort studies

Author, year | Representativeness of the exposed cohort | Selection of the non exposed cohort | Ascertainment of exposure | Outcome of interest not present at start of study | Comparability of cohorts | Assessment of outcome | Follow-up long enough to occur | Adequacy of follow up of cohorts
Badart-Smook A, et al, 1997^47^ | Truly representative | Not applicable | Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | Complete follow-up
Bakker EC, et al, 2003^163^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Independent blind assessment | Yes | Subjects lost to follow up unlikely to introduce bias
Bakker EC, et al, 2009^134^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for most important factor | Independent blind assessment | Yes | Follow up rate < 80% (select an adequate %) and no description of those lost
Bernard JY, et al, 2013^89^ | Somewhat representative | Not applicable | Written self report | Yes | Controls for most important factor and other factors | Independent blind assessment | Yes | Follow up rate < 80% (select an adequate %) and no description of those lost
Bouwstra H, et al, 2006^133^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for most important factor | Independent blind assessment | Yes | Subjects lost to follow up unlikely to introduce bias
Brantsaeter AL, et al, 2012^81^ | Somewhat representative | Not applicable | Structured interview | Yes | Controls for most important factor and other factors | Self report | Yes | No statement
Chong MF, et al, 2015^95^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Clausen T, et al, 2001^68^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Independent blind assessment | Yes | Complete follow-up
Dirix CE, et al, 2009^84^ | Truly representative | Not applicable | Secure record | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Drouillet P, et al, 2009^80^ | Truly representative | Not applicable | Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Guxens M, et al, 2011^144^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Independent blind assessment | Yes | Subjects lost to follow up unlikely to introduce bias
Jordi Julvez, et al, 2014^143^ | Truly representative | Not applicable | Secure record | Yes | Controls for most important factor and other factors | Independent blind assessment | Yes | Follow up rate < 80% (select an adequate %) and no description of those lost
Keim SA, et al, 2012^162^ | Somewhat representative | Not applicable | Secure record | Yes | Controls for most important factor and other factors | Independent blind assessment | Yes | Follow up rate < 80% (select an adequate %) and no description of those lost
Klebanoff MA, et al, 2011^49^ | Truly representative | Drawn from same community | Secure record, Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | Complete follow-up
Leung BM, et al, 2013^94^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Self report | No | Subjects lost to follow up unlikely to introduce bias
Lim WY, et al, 2015^71^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Independent blind assessment | Yes | Follow up rate < 80% (select an adequate %) and no description of those lost
Lumia M, et al, 2011^188^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor | Record linkage | Yes | Follow up rate < 80% (select an adequate %) and no description of those lost
yall K, et al, 2013^171^ | Selected group | Not applicable | Written self report | Yes | Controls for most important factor and other factors | Self report | Yes | Follow up rate < 80% (select an adequate %) and no description of those lost
Miyake Y, et al, 2009^182^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Self report | No | Subjects lost to follow up unlikely to introduce bias
Miyake Y, et al, 2013^183^ | Somewhat representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Self report | No | Subjects lost to follow up unlikely to introduce bias
Mohanty AF, et al, 2015^85^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Molto-Puigmarti C, et al, 2014^48^ | Truly representative | Not applicable | Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Morales E, et al, 2012^184^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Self report | No | Subjects lost to follow up unlikely to introduce bias
Much D, et al, 2013^101^ | No description of the derivation of cohort | Not applicable | No description | Yes | Controls for most important factor | Independent blind assessment | Yes | Subjects lost to follow up unlikely to introduce bias
Much D, et al, 2013^83^ | No description of the derivation of cohort | Not applicable | Secure record | Yes | Controls for most important factor and other factors | Independent blind assessment | Yes | Subjects lost to follow up unlikely to introduce bias
Muthayya S, et al, 2009^72^ | Truly representative | Not applicable | Secure record | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Newson RB, et al, 2004^176^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor | Independent blind assessment and self report | Yes | No statement
Notenboom ML, et al, 2011^179^ | Somewhat representative | Not applicable | Secure record | Yes | Controls for most important factor and other factors | Record linkage and self report | Yes | Subjects lost to follow up unlikely to introduce bias
Nwaru BI, et al, 2012^180^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Self report | Yes | No statement
Oken E, et al, 2004^46^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | No statement
Oken E, et al, 2007^69^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Olafsdottir AS, et al, 2005^82^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Record linkage and self report | Yes | Complete follow-up
Olafsdottir AS, et al, 2006^70^ | Somewhat representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Parker G, Hegarty B, et al, 2015^97^ | Truly representative | Not applicable | Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | Subjects lost to follow up unlikely to introduce bias
Pike KC, et al, 2012^186^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor | Record linkage and self report | Yes | Subjects lost to follow up unlikely to introduce bias
Saito K, et al, 2010^181^ | Somewhat representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Self report | Yes | Subjects lost to follow up unlikely to introduce bias
Sallis H, et al, 2014^96^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Record linkage | Yes | No statement
Scholtens S, et al, 2009^103^ | Selected group | Not applicable | Secure record | Yes | Controls for most important factor and other factors | Record linkage | Yes | Follow up rate < 80% (select an adequate %) and no description of those lost
Smits LJ, et al, 2013^73^ | Truly representative | Not applicable | Secure record | Yes | Controls for most important factor and other factors | No description | Yes | No statement
Standl M, et al, 2014^177^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Self report | Yes | Subjects lost to follow up unlikely to introduce bias
Steer CD, et al, 2013^164^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor | Record linkage | Yes | No statement
Strom M, et al, 2009^92^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Record linkage | Yes | No statement
Sun Y, et al, 2010^131^ | Truly representative | Not applicable | Written self report | Yes | Controls for most important factor and other factors | Record linkage | Yes | Complete follow-up
Thijs C, et al, 2011^178^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Record linkage and self report | Yes | Subjects lost to follow up unlikely to introduce bias
Valent F, et al, 2013^132^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | No description | Yes | Subjects lost to follow up unlikely to introduce bias
Wijga AH, et al, 2006^175^ | Truly representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Independent blind assessment and self report | Yes | Subjects lost to follow up unlikely to introduce bias
Yoshihiro Miyake, et al, 2006^93^ | Truly representative | Drawn from same community | Structured interview | Yes | Controls for most important factor and other factors | Self report | Yes | Subjects lost to follow up unlikely to introduce bias
Yu YM, et al, 2015^185^ | Somewhat representative | Drawn from same community | Secure record | Yes | Controls for most important factor and other factors | Record linkage and self report | Yes | Subjects lost to follow up unlikely to introduce bias

Table F3 Quality assessment of studies reporting harms

Author, year | Were the harms predefined using standardized or precise definitions? | Was the mode of harms collected specified as active? | Was the potential occurrence of harmful events collected at pre-specified intervals? | Did the author(s) specify the NUMBER for each TYPE of harmful event for each study group? | Was the TOTAL NUMBER of participants affected by harms specified for each study arm? | If the study reported that there were no serious AE's reported did they define serious AEs?
Agostoni C, et al, 2009^139^ | No | No | Yes | Yes | Yes | No
Birch EE, et al, 2005^111^ | No | Unclear | Unclear | Yes | Yes | Not applicable
Birch EE, et al, 2010^121^ | No | Unclear | Yes | No | Yes | Yes
Carlson SE, et al, 2013^31^ | Yes | Yes | Unclear | Yes | Yes | Not applicable
Clandinin MT, et al, 2005^108^ | Unclear | No | Unclear | Yes | Yes | Not applicable
Dunstan JA, et al, 2003^50^ | No | No | No | Yes | Yes | Not applicable
Escolano-Margarit MV, et al, 2011^130^ | Unclear | Unclear | Unclear | No | Yes | Not applicable
Fang PC, et al, 2005^137^ | No | No | Yes | No | No | No
Field CJ, et al, 2008^112^ | No | No | No | No | No | Not applicable
Fleddermann M, et al, 2014^113^ | Yes | Yes | Unclear | Yes | Yes | Not applicable
Furuhjelm C, et al, 2009^173^ | No | No | No | Yes | Yes | No
Furuhjelm C, et al, 2011^172^ | No | No | No | Yes | No | No
Harper M, et al, 2010^29^ | Yes | Yes | Yes | Yes | No | Unclear
Henriksen C, et al, 2008^107^ | No | Unclear | Yes | No | No | Not applicable
Hoffman D, et al, 2008^114^ | Yes | Unclear | Yes | Yes | No | Not applicable
Imhoff-Kunsch B, et al, 2011^58^ | Yes | Yes | Yes | Yes | Yes | Not applicable
Llorente AM, et al, 2003^98^ | No | Unclear | Unclear | No | No | No
Makrides M, et al, 2009^116^ | Yes | Yes | Unclear | Yes | Yes | Not applicable
Makrides M, et al, 2010^35^ | Yes | Yes | Yes | Yes | Yes | Not applicable
Ramakrishnan U, et al, 2010^32^ | Yes | Yes | Yes | Yes | Yes | No