# Appendix E Data Abstraction Tools

1 Data Abstraction Tool

2 Data Abstraction Tool for Observational Studies

3 Modified Cochrane Risk of Bias Tool

4 Modified Newcastle-Ottawa Quality Assessment Scale

5 McHarms Tool