# Appendix D Evidence Table for Observational Studies

Table D1 Evidence table for observational studies