# Appendix C Evidence Table for Randomized Controlled Trials

Table C1 Evidence table for randomized controlled trials