# Appendix B List of Excluded Studies

This appendix lists all studies (publications) that were identified in our literature searches that were subsequently excluded during abstract or full-text screening. Among these excluded publications were some that were included in the original report. Most of the studies included in the original report were subsequently included in our analyses, but for the sole purpose of tracking the article flow from our literature searches and the reasons for exclusion, we counted the publications from the original report that appeared in our searches as having been excluded.

## Studies included in the original report that were also identified in our searches – N=31

1 Agostoni C, Marangoni F, Giovannini M, et al. (2001). Prolonged breast-feeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol.
2 Auestad N, Halter R, Hall RT, et al. (2001). Growth and development in term infants fed long-chain polyunsaturated fatty acids: a double-masked, randomized, parallel, prospective, multivariate study. Pediatrics.
3 Auestad N, Scott DT, Janowsky JS, et al. (2003). Visual, cognitive, and language assessments at 39 months: a follow-up study of children fed formulas containing long-chain polyunsaturated fatty acids to 1 year of age. Pediatrics.
4 Birch EE, Birch DG, Hoffman DR, et al. (1992). Dietary essential fatty acid supply and visual acuity development. Invest Ophthalmol Vis Sci.
5 Birch EE, Garfield S, Hoffman DR, et al. (2000). A randomized controlled trial of early dietary supply of long-chain polyunsaturated fatty acids and mental development in term infants. Dev Med Child Neurol.
6 Birch EE, Hoffman DR, Castaneda YS, et al. (2002). A randomized controlled trial of long-chain polyunsaturated fatty acid supplementation of formula in term infants after weaning at 6 wk of age. Am J Clin Nutr.
7 Carlson SE, Werkman SH, Rhodes PG, et al. (1993). Visual-acuity development in healthy preterm infants: effect of marine-oil supplementation. Am J Clin Nutr.
8 de Groot RH, Hornstra G, van Houwelingen AC, et al. (2004). Effect of alpha-linolenic acid supplementation during pregnancy on maternal and neonatal polyunsaturated fatty acid status and pregnancy outcome. Am J Clin Nutr.
9 Fewtrell MS, Abbott RA, Kennedy K, et al. (2004). Randomized, double-blind trial of long-chain polyunsaturated fatty acid supplementation with fish oil and borage oil in preterm infants. J Pediatr.
10 Fewtrell MS, Morley R, Abbott RA, et al. (2002). Double-blind, randomized trial of long-chain polyunsaturated fatty acid supplementation in formula fed to preterm infants. Pediatrics.
11 Ghys A, Bakker E, Hornstra G, et al. (2002). Red blood cell and plasma phospholipid arachidonic and docosahexaenoic acid levels at birth and cognitive development at 4 years of age. Early Hum Dev.
12 Helland IB, Saugstad OD, Smith L, et al. (2001). Similar effects on infants of n-3 and n-6 fatty acids supplementation to pregnant and lactating women. Pediatrics.
13 Helland IB, Smith L, Saarem K, et al. (2003). Maternal supplementation with very-long-chain n-3 fatty acids during pregnancy and lactation augments children's IQ at 4 years of age. Pediatrics.
14 Hoffman DR, Birch EE, Birch DG, et al. (2000). Impact of early dietary intake and blood lipid composition of long-chain polyunsaturated fatty acids on later visual development. J Pediatr Gastroenterol Nutr.
15 Innis SM, Adamkin DH, Hall RT, et al. (2002). Docosahexaenoic acid and arachidonic acid enhance growth with no adverse effects in preterm infants fed formula. J Pediatr.
16 Innis SM, Gilley J, Werker J. (2001). Are human milk long-chain polyunsaturated fatty acids related to visual and neural development in breast-fed term infants?. J Pediatr.
17 Koletzko B, Sauerwald U, Keicher U, et al. (2003). Fatty acid profiles, antioxidant status, and growth of preterm infants fed diets without or with long-chain polyunsaturated fatty acids. A randomized clinical trial. Eur J Nutr.
18 Makrides M, Neumann MA, Jeffrey B, et al. (2000). A randomized trial of different ratios of linoleic to alpha-linolenic acid in the diet of term infants: effects on visual function and growth. Am J Clin Nutr.
19 Makrides M, Neumann MA, Simmer K, et al. (2000). A critical appraisal of the role of dietary long-chain polyunsaturated fatty acids on neural indices of term infants: a randomized, controlled trial. Pediatrics.
20 Malcolm CA, Hamilton R, McCulloch DL, et al. (2003). Scotopic electroretinogram in term infants born of mothers supplemented with docosahexaenoic acid during pregnancy. Invest Ophthalmol Vis Sci.
21 Morris G, Moorcraft J, Mountjoy A, et al. (2000). A novel infant formula milk with added long-chain polyunsaturated fatty acids from single-cell sources: a study of growth, satisfaction and health. Eur J Clin Nutr.
22 O'Connor DL, Hall R, Adamkin D, et al. (2001). Growth and development in preterm infants fed long-chain polyunsaturated fatty acids: a prospective, randomized controlled trial. Pediatrics.
23 Olsen SF, Secher NJ, Tabor A, et al. (2000). Randomised clinical trials of fish oil supplementation in high risk pregnancies. Fish Oil Trials In Pregnancy (FOTIP) Team. BJOG.
24 Rocquelin G, Tapsoba S, Kiffer J, et al. (2003). Human milk fatty acids and growth of infants in Brazzaville (The Congo) and Ouagadougou (Burkina Faso). Public Health Nutr.
25 SanGiovanni JP, Parra-Cabrera S, Colditz GA, et al. (2000). Meta-analysis of dietary essential fatty acids and long-chain polyunsaturated fatty acids as they relate to visual resolution acuity in healthy preterm infants. Pediatrics.
26 Smuts CM, Huang M, Mundy D, et al. (2003). A randomized trial of docosahexaenoic acid supplementation during the third trimester of pregnancy. Obstet Gynecol.
27 van Wezel-Meijler G, van der Knaap MS, Huisman J, et al. (2002). Dietary supplementation of long-chain polyunsaturated fatty acids in preterm infants: effects on cerebral maturation. Acta Paediatr.
28 Vanderhoof J, Gross S, Hegyi T. (2000). A multicenter long-term safety and efficacy trial of preterm formula supplemented with long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr.
29 Voigt RG, Jensen CL, Fraley JK, et al. (2002). Relationship between omega3 long-chain polyunsaturated fatty acid status during early infancy and neurodevelopmental status at 1 year of age. J Hum Nutr Diet.
30 Williams C, Birch EE, Emmett PM, et al. (2001). Stereoacuity at age 3.5 y in children born full-term is associated with prenatal and postnatal dietary factors: a report from a population-based cohort study. Am J Clin Nutr.
31 Xiang M, Alfven G, Blennow M, et al. (2000). Long-chain polyunsaturated fatty acids in human milk and brain growth during early infancy. Acta Paediatr.

## Not a human study- N=4

1 Das UN. (2003). Can memory be improved? A discussion on the role of ras, GABA, acetylcholine, NO, insulin, TNF-α, and long-chain polyunsaturated fatty acids in memory formation and consolidation. Brain Dev.
2 Field CJ, Van Aerde JE, Robinson LE, et al. (2008). Feeding a formula supplemented with long chain polyunsaturated fatty acids modifies the “ex vivo” cytokine responses to food proteins in infants at low risk for allergy. Pediatr Res.
3 Fu Z, Lofqvist CA, Shao Z, et al. (2015). Dietary omega-3 polyunsaturated fatty acids decrease retinal neovascularization by adipose-endoplasmic reticulum stress reduction to increase adiponectin. Am J Clin Nutr.
4 Russell KL. (2014). N-3 fatty acids and juvenile traumatic brain injury: Effects of dietary n-3 fatty acid content, n-3 fatty acid status, and orally dosed fish oil on sensorimotor and biochemical outcomes. Dissertation Abstracts International: Section B: The Sciences and Engineering.

## Not omega-3 - N=53

1 Akobeng Anthony K, Thomas Adrian G. (2007). Enteral nutrition for maintenance of remission in Crohn's disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd.
2 Andres A, Casey PH, Cleves MA, et al. (2013). Body fat and bone mineral content of infants fed breast milk, cow's milk formula, or soy formula during the first year of life. J Pediatr.
3 Arslanoglu S, Moro GE, Ziegler EE. (2006). Adjustable fortification of human milk fed to preterm infants: does it make a difference?. J Perinatol.
4 Benefice E, Monrroy SJ, Rodriguez RW. (2008). A nutritional dilemma: fish consumption, mercury exposure and growth of children in Amazonian Bolivia. Int J Environ Health Res.
5 Bitsanis D, Ghebremeskel K, Moodley T, et al. (2006). Gestational diabetes mellitus enhances arachidonic and docosahexaenoic acids in placental phospholipids. Lipids.
6 Brookes KJ, Chen W, Xu X, et al. (2006). Association of fatty acid desaturase genes with attention-deficit/hyperactivity disorder. Biol Psychiatry.
7 Brown CM, Austin DW, Busija L. (2014). Observable essential fatty acid deficiency markers and autism spectrum disorder. Breastfeed Rev.
8 Burns J, Boogaard H, Turley R, et al. (2014). Interventions to reduce ambient particulate matter air pollution and their effect on health. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd.
9 Caritis SN, Venkataramanan R, Thom E, et al. (2014). Relationship between 17-alpha hydroxyprogesterone caproate concentration and spontaneous preterm birth. Am J Obstet Gynecol.
10 Chisaguano AM, Montes R, Castellote AI, et al. (2014). Elaidic, vaccenic, and rumenic acid status during pregnancy: association with maternal plasmatic LC-PUFAs and atopic manifestations in infants. Pediatr Res.
11 Colome G, Sierra C, Blasco J, et al. (2007). Intestinal permeability in different feedings in infancy. Acta Paediatr.
12 D'Auria E, Sala M, Lodi F, et al. (2003). Nutritional value of a rice-hydrolysate formula in infants with cows' milk protein allergy: a randomized pilot study. J Int Med Res.
13 Dennis CL, Dowswell T. (2013). Interventions (other than pharmacological, psychosocial or psychological) for treating antenatal depression. Cochrane Database of Systematic Reviews.
14 Després C, Beuter A, Richer F, et al. (2005). Neuromotor functions in Inuit preschool children exposed to Pb, PCBs, and Hg. Neurotoxicol Teratol.
15 Dotterud CK, Storro O, Simpson MR, et al. (2013). The impact of pre- and postnatal exposures on allergy related diseases in childhood: a controlled multicentre intervention study in primary health care. BMC Public Health.
16 Fomon SJ, Thomas LN, Filer LJ, et al. (1971). Food consumption and growth of normal infants fed milk-based formulas. Acta Paediatr Scand.
17 Ford JH. (2011). Preconception risk factors and SGA babies: Papilloma virus, omega 3 and fat soluble vitamin deficiencies. Early Hum Dev.
18 Fugh-Berman A, Kronenberg F. (2003). Complementary and alternative medicine (CAM) in reproductive-age women: a review of randomized controlled trials. Reprod Toxicol.
19 Garcia-Marcos L, Castro-Rodriguez JA, Weinmayr G, et al. (2013). Influence of Mediterranean diet on asthma in children: a systematic review and meta-analysis. Pediatr Allergy Immunol.
20 Heppe DH, Kiefte-de Jong JC, Durmus B, et al. (2013). Parental, fetal, and infant risk factors for preschool overweight: the Generation R Study. Pediatr Res.
21 Klenoff-Brumberg HL, Genen LH. (2003). High versus low medium chain triglyceride content of formula for promoting short term growth of preterm infants. Cochrane Database of Systematic Reviews.
22 Koo WW, Hammami M, Margeson DP, et al. (2003). Reduced bone mineralization in infants fed palm olein-containing formula: a randomized, double-blinded, prospective trial. Pediatrics.
23 Laitinen K, Hoppu U, Hamalainen M, et al. (2006). Breast milk fatty acids may link innate and adaptive immune regulation: analysis of soluble CD14, prostaglandin E2, and fatty acids. Pediatr Res.
24 Lasekan J, Baggs G, Acosta S, et al. (2015). Soy protein-based infant formulas with supplemental fructooligosaccharides: Gastrointestinal tolerance and hydration status in newborn infants. Nutrients.
25 Lassi Zohra S, Salam Rehana A, Haider Batool A, et al. (2013). Folic acid supplementation during pregnancy for maternal health and pregnancy outcomes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd.
26 Linday LA. (2010). Cod liver oil, young children, and upper respiratory tract infections. J Am Coll Nutr.
27 Luoto R, Kinnunen TI, Aittasalo M, et al. (2011). Primary prevention of gestational diabetes mellitus and large-for-gestational-age newborns by lifestyle counseling: a cluster-randomized controlled trial. PLoS Medicine / Public Library of Science.
28 Lynch ML, Huang LS, Cox C, et al. (2011). Varying coefficient function models to explore interactions between maternal nutritional status and prenatal methylmercury toxicity in the Seychelles Child Development Nutrition Study. Environ Res.
29 Martinez-Gonzalez MA, Bes-Rastrollo M. (2011). Nut consumption, weight gain and obesity: Epidemiological evidence. Nutrition Metabolism & Cardiovascular Diseases.
30 Mendez MA, Anthony MS, Arab L. (2002). Soy-based formulae and infant growth and development: a review. J Nutr.
31 Mikkelsen TB, Osterdal ML, Knudsen VK, et al. (2008). Association between a Mediterranean-type diet and risk of preterm birth among Danish women: a prospective cohort study. Acta Obstet Gynecol Scand.
32 Muche-Borowski C, Kopp M, Reese I, et al. (2009). Allergy prevention. Deutsches Arzteblatt International.
33 Muche-Borowski C, Kopp M, Reese I, et al. (2010). Allergy prevention. Journal der Deutschen Dermatologischen Gesellschaft.
34 Muckle G, Ayotte P, Dewailly EE, et al. (2001). Prenatal exposure of the northern Quebec Inuit infants to environmental contaminants. Environ Health Perspect.
35 Murrin C, Shrivastava A, Kelleher CC, et al. (2013). Maternal macronutrient intake during pregnancy and 5 years postpartum and associations with child weight status aged five. Eur J Clin Nutr.
36 Nachmias N, Landman Y, Danon YL, et al. (2010). Soy allergy following early soy feeding in neonates. Israel Medical Association Journal: Imaj.
37 Netting MJ, Middleton PF, Makrides M. (2014). Does maternal diet during pregnancy and lactation affect outcomes in offspring? A systematic review of food-based approaches. Nutrition.
38 Niinivirta K, Isolauri E, Laakso P, et al. (2011). Dietary counseling to improve fat quality during pregnancy alters maternal fat intake and infant essential fatty acid status. J Nutr.
39 Piacentini G, Peroni D, Bessi E, et al. (2010). Molecular characterization of intestinal microbiota in infants fed with soymilk. J Pediatr Gastroenterol Nutr.
40 Qureshi NA, Al-Bedah AM. (2013). Mood disorders and complementary and alternative medicine: A literature review. Neuropsychiatr Dis Treat.
41 Rask-Nissila L, Jokinen E, Terho P, et al. (2002). Effects of diet on the neurologic development of children at 5 years of age: the STRIP project. J Pediatr.
42 Rumbold A, Duley L, Crowther Caroline A, et al. (2008). Antioxidants for preventing pre-eclampsia. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd.
43 Say L, Gülmezoglu AM, Hofmeyr GJ. (2003). Maternal nutrient supplementation for suspected impaired fetal growth. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd.
44 Scholl TO, Leskiw M, Chen X, et al. (2005). Oxidative stress, diet, and the etiology of preeclampsia. Am J Clin Nutr.
45 Shoji H, Hisata K, Suzuki M, et al. (2011). Effects of parenteral soybean oil lipid emulsion on the long-chain polyunsaturated fatty acid profile in very-low-birth-weight infants. Acta Paediatr.
46 Simpson A, Custovic A. (2004). Allergen avoidance in the primary prevention of asthma. Curr Opin Allergy Clin Immunol.
47 Suren P, Roth C, Bresnahan M, et al. (2013). Association between maternal use of folic acid supplements and risk of autism spectrum disorders in children. JAMA.
48 Suzuki K, Nakai K, Sugawara T, et al. (2010). Neurobehavioral effects of prenatal exposure to methylmercury and PCBs, and seafood intake: neonatal behavioral assessment scale results of Tohoku study of child development. Environ Res.
49 Tofail F, Hamadani JD, Ahmed AZ, et al. (2012). The mental development and behavior of low-birth-weight Bangladeshi infants from an urban low-income community. Eur J Clin Nutr.
50 Tomedi LE, Chang CC, Newby PK, et al. (2013). Pre-pregnancy obesity and maternal nutritional biomarker status during pregnancy: a factor analysis. Public Health Nutr.
51 Trock BJ, Hilakivi-Clarke L, Clarke R. (2006). Meta-analysis of soy intake and breast cancer risk. J Natl Cancer Inst.
52 Wang H, Jiang H, Yang L, et al. (2015). Impacts of dietary fat changes on pregnant women with gestational diabetes mellitus: a randomized controlled study. Asia Pac J Clin Nutr.
53 Zachos M, Tondeur M, Griffiths Anne M. (2007). Enteral nutritional therapy for induction of remission in Crohn's disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd.

## Not in English- N=1

1 Patin RV, Vitolo MR, Valverde MA, et al. (2006). The influence of sardine consumption on the omega-3 fatty acid content of mature human milk. Jornal de Pediatria.

## Treatment study, not prevention/risk study - N=29

1 Anderson G, Maes M. (2013). Postpartum depression: Psychoneuroimmunological underpinnings and treatment. Neuropsychiatr Dis Treat.
2 Belanger SA, Vanasse M, Spahis S, et al. (2009). Omega-3 fatty acid treatment of children with attention-deficit hyperactivity disorder: A randomized, double-blind, placebo-controlled study. Paediatr Child Health.
3 Bent S, Bertoglio K, Hendren RL. (2009). Omega-3 fatty acids for autistic spectrum disorder: a systematic review. J Autism Dev Disord.
4 Bent S, Bertoglio K, Hendren RL. (2009). Omega-3 fatty acids for autism spectrum disorder: A systematic review. J Autism Dev Disord.
5 Bent S, Hendren RL, Zandi T, et al. (2014). Internet-based, randomized, controlled trial of omega-3 fatty acids for hyperactivity in autism. J Am Acad Child Adolesc Psychiatry.
6 Clayton EH, Hanstock TL, Garg ML, et al. (2007). Long chain omega-3 polyunsaturated fatty acids in the treatment of psychiatric illnesses in children and adolescents. Acta Neuropsychiatrica.
7 Covar R, Gleason M, Macomber B, et al. (2010). Impact of a novel nutritional formula on asthma control and biomarkers of allergic airway inflammation in children. Clin Exp Allergy.
8 Curtis LT, Patel K. (2008). Nutritional and environmental approaches to preventing and treating autism and attention deficit hyperactivity disorder (ADHD): A review. The Journal of Alternative and Complementary Medicine.
9 Freeman MP, Hibbeln JR, Wisner KL, et al. (2006). Omega-3 fatty acids: Evidence basis for treatment and future research in psychiatry. J Clin Psychiatry.
10 Gil-Campos M, Sanjurjo Crespo P. (2012). Omega 3 fatty acids and inborn errors of metabolism. Br J Nutr.
11 Gool CJ, Zeegers MP, Thijs C. (2004). Oral essential fatty acid supplementation in atopic dermatitis: a meta-analysis of placebo-controlled trials. Br J Dermatol.
12 Gustafsson PA, Birberg-Thornberg U, Duchen K, et al. (2010). EPA supplementation improves teacher-rated behaviour and oppositional symptoms in children with ADHD. Acta Paediatr.
13 James S, Montgomery P, Williams K. (2011). Omega-3 fatty acids supplementation for autism spectrum disorders (ASD). Cochrane Database of Systematic Reviews.
14 Johnson M, Mansson JE, Ostlund S, et al. (2012). Fatty acids in ADHD: plasma profiles in a placebo-controlled study of Omega 3/6 fatty acids in children and adolescents. Attention Deficit and Hyperactivity Disorders.
15 Mankad D, Dupuis A, Smile S, et al. (2015). A randomized, placebo controlled trial of omega-3 fatty acids in the treatment of young children with autism. Mol Autism.
16 Manor I, Magen A, Keidar D, et al. (2013). Safety of phosphatidylserine containing omega3 fatty acids in ADHD children: a double-blind placebo-controlled trial followed by an open-label extension. European Psychiatry: the Journal of the Association of European Psychiatrists.
17 Meldrum SJ, D'Vaz N, Dunstan J, et al. (2011). The Infant Fish Oil Supplementation Study (IFOS): design and research protocol of a double-blind, randomised controlled n--3 LCPUFA intervention trial in term infants. Contemp Clin Trials.
18 Oliver C, Watson H. (2013). Omega-3 fatty acids for cystic fibrosis. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd.
19 Ooi YP, Weng SJ, Jang LY, et al. (2015). Omega-3 fatty acids in the management of autism spectrum disorders: findings from an open-label pilot study in Singapore. Eur J Clin Nutr.
20 Politi P, Rocchetti M, Emanuele E, et al. (2013). Randomized placebo-controlled trials of omega-3 polyunsaturated fatty acids in psychiatric disorders: a review of the current literature. Current Drug Discovery Technologies.
21 Raz R, Carasso RL, Yehuda S. (2009). The influence of short-chain essential fatty acids on children with attention-deficit/hyperactivity disorder: a double-blind placebo-controlled study. J Child Adolesc Psychopharmacol.
22 Raz R, Gabis L. (2009). Essential fatty acids and attention-deficit-hyperactivity disorder: a systematic review. Dev Med Child Neurol.
23 Sinn N, Bryan J, Wilson C. (2008). Cognitive effects of polyunsaturated fatty acids in children with attention deficit hyperactivity disorder symptoms: a randomised controlled trial. Prostaglandins Leukotrienes & Essential Fatty Acids.
24 Smith LJ, Kalhan R, Wise RA, et al. (2015). Effect of a soy isoflavone supplement on lung function and clinical outcomes in patients with poorly controlled asthma: a randomized clinical trial. JAMA.
25 Spahis S, Vanasse M, Belanger SA, et al. (2008). Lipid profile, fatty acid composition and pro- and anti-oxidant status in pediatric patients with attention-deficit/hyperactivity disorder. Prostaglandins Leukotrienes & Essential Fatty Acids.
26 Transler C, Eilander A, Mitchell S, et al. (2010). The impact of polyunsaturated fatty acids in reducing child attention deficit and hyperactivity disorders. Journal of Attention Disorders.
27 Tsuchimine S, Saito M, Kaneko S, et al. (2015). Decreased serum levels of polyunsaturated fatty acids and folate, but not brain-derived neurotrophic factor, in childhood and adolescent females with depression. Psychiatry Res.
28 van Gool CJ, Zeegers MP, Thijs C. (2004). Oral essential fatty acid supplementation in atopic dermatitis-a meta-analysis of placebo-controlled trials. Br J Dermatol.
29 Wu Q, Zhou T, Ma L, et al. (2015). Protective effects of dietary supplementation with natural omega-3 polyunsaturated fatty acids on the visual acuity of school-age children with lower IQ or attention-deficit hyperactivity disorder. Nutrition.

## Study design - N=53

1 Al-Tamer YY, Mahmood AA. (2004). Fatty-acid composition of the colostrum and serum of fullterm and preterm delivering Iraqi mothers. Eur J Clin Nutr.
2 Arnold LE. (2011). Fish oil is not snake oil. J Am Acad Child Adolesc Psychiatry.
3 Bawadi HA, Al-Kuran O, Al-Bastoni LA, et al. (2010). Gestational nutrition improves outcomes of vaginal deliveries in Jordan: an epidemiologic screening. Nutr Res.
4 Beck M, Zelczak G, Lentze MJ. (2000). Abnormal fatty acid composition in umbilical cord blood of infants at high risk of atopic disease. Acta Paediatr.
5 Berman D, Limb R, Somers E, et al. (2015). Prenatal omega-3 supplementation and risk of eczema among offspring at age 36 months: Long-term follow-up of the mothers, omega-3, & mental health trial. Am J Obstet Gynecol.
6 Best K, Makrides M, Gold M. (2014). Effect of maternal dietary long chain polyunsaturated fatty acid intake during pregnancy on clinical outcomes of allergic disease in the offspring: A systematic review. Intern Med J.
7 Best K, Sullivan T, Gold M, et al. (2015). Six-year follow up of children at high hereditary risk of allergy, born to mothers supplemented with docosahexaenoic acid (DHA) in the domino trial. J Paediatr Child Health.
8 Bjerve KS, Thoresen L, Bonaa K, et al. (1992). Clinical studies with alpha-linolenic acid and long-chain n-3 fatty acids. Nutrition.
9 Bodnar LM, Wisner KL, Luther JF, et al. (2012). An exploratory factor analysis of nutritional biomarkers associated with major depression in pregnancy. Public Health Nutr.
10 Brigandi SA, Shao H, Qian SY, et al. (2015). Autistic children exhibit decreased levels of essential Fatty acids in red blood cells. Int J Mol Sci.
11 Carlsen K, Pedersen L, Bonnelykke K, et al. (2013). Association between whole-blood polyunsaturated fatty acids in pregnant women and early fetal weight. Eur J Clin Nutr.
12 Cosatto VF, Else PL, Meyer BJ. (2010). Do pregnant women and those at risk of developing post-natal depression consume lower amounts of long chain omega-3 polyunsaturated fatty acids?. Nutrients.
13 Crawford MA, Costeloe K, Doyle W, et al. (1990). Potential diagnostic value of the umbilical artery as a definition of neural fatty acid status of the fetus during its growth: the umbilical artery as a diagnostic tool. Biochem Soc Trans.
14 Crawford MA, Doyle W, Drury P, et al. (1989). n-6 and n-3 fatty acids during early human development. J Intern Med.
15 Dirix CE, Kester AD, Hornstra G. (2009). Associations between term birth dimensions and prenatal exposure to essential and trans fatty acids. Early Hum Dev.
16 Drover JR. (2012). ‘Three randomized controlled trials of early long-chain polyunsaturated fatty acid supplementation on means-end problem solving in nine month-olds’: Addendum. Child Dev.
17 Felton CV, Chang TC, Crook D, et al. (1994). Umbilical vessel wall fatty acids after normal and retarded fetal growth. Archives of Disease in Childhood Fetal & Neonatal Edition.
18 Gianni ML, Roggero P, Baudry C, et al. (2012). The influence of a formula supplemented with dairy lipids and plant oils on the erythrocyte membrane omega-3 fatty acid profile in healthy full-term infants: a double-blind randomized controlled trial. BMC Pediatr.
19 Grigoriadis S, Barrett J, Pittini R, et al. (2010). Omega-3 supplements in pregnancy: are we too late to identify the possible benefits?. Journal of Obstetrics & Gynaecology Canada: JOGC.
20 Haby MM, Peat JK, Marks GB, et al. (2001). Asthma in preschool children: prevalence and risk factors. Thorax.
21 Harper M. (2007). Randomized controlled trial of omega-3 fatty acid supplementation for recurrent preterm birth prevention. Am J Obstet Gynecol.
22 Harper M. (2009). Low maternal omega-3 levels prior to 22 weeks' gestation are associated with preterm delivery and low fish intake. Am J Obstet Gynecol.
23 Hauner H, Vollhardt C, Schneider KT, et al. (2009). The impact of nutritional fatty acids during pregnancy and lactation on early human adipose tissue development. Rationale and design of the INFAT study. Ann Nutr Metab.
24 Iranpour R, Kelishadi R, Babaie S, et al. (2013). Comparison of long chain polyunsaturated fatty acid content in human milk in preterm and term deliveries and its correlation with mothers' diet. J Res Med Sci.
25 Kar S, Thangaratinam S, Wong M, et al. (2014). Can essential fatty acids prevent early preterm delivery? A meta-analysis of evidence (Provisional abstract). Database of Abstracts of Reviews of Effects.
26 Kazemian E, Dorosty-Motlagh AR, Sotoudeh G, et al. (2013). Nutritional status of women with gestational hypertension compared with normal pregnant women. Hypertens Pregnancy.
27 Keim SA. (2009). Long-chain polyunsaturated fatty acids in breast milk and infant formula, maternal perinatal mental health, and infant development. Dissertation Abstracts International: Section B: The Sciences and Engineering.
28 Kirby A, Woodward A, Jackson S, et al. (2010). Childrens' learning and behaviour and the association with cheek cell polyunsaturated fatty acid levels. Res Dev Disabil.
29 Koletzko B, Braun M. (1991). Arachidonic acid and early human growth: is there a relation?. Ann Nutr Metab.
30 Kovacs A, Funke S, Marosvolgyi T, et al. (2005). Fatty acids in early human milk after preterm and full-term delivery. J Pediatr Gastroenterol Nutr.
31 Kramer MS, Kahn SR, Platt RW, et al. (2009). Antioxidant vitamins, long-chain fatty acids, and spontaneous preterm birth. Epidemiology.
32 Kuipers RS, Luxwolda MF, Dijck-Brouwer DA, et al. (2011). Differences in preterm and term milk fatty acid compositions may be caused by the different hormonal milieu of early parturition. Prostaglandins Leukotrienes & Essential Fatty Acids.
33 Kuriki K, Nagaya T, Tokudome Y, et al. (2003). Plasma concentrations of (n-3) highly unsaturated fatty acids are good biomarkers of relative dietary fatty acid intakes: a cross-sectional study. J Nutr.
34 Labadaridis I, Moraitou M, Theodoraki M, et al. (2007). Linoleic and arachidonic acid in perinatal asphyxia and prematurity. J Matern Fetal Neonatal Med.
35 Lauritzen L, Halkjaer LB, Mikkelsen TB, et al. (2006). Fatty acid composition of human milk in atopic Danish mothers. Am J Clin Nutr.
36 Lof M, Hilakivi-Clarke L, Sandin SS, et al. (2009). Dietary fat intake and gestational weight gain in relation to estradiol and progesterone plasma levels during pregnancy: a longitudinal study in Swedish women. BMC Womens Health.
37 Marangell LB, Martinez JM, Zboyan HA, et al. (2004). Omega-3 Fatty Acids for the Prevention of Postpartum Depression: Negative Data From a Preliminary, Open-Label Pilot Study. Depress Anxiety.
38 McCulloch D, Malcolm CA, Montgomery C, et al. (2002). Maternal fish oil supplementation and visual maturation in term infants. American Academy of Optometry.
39 Mehendale S, Kilari A, Dangat K, et al. (2008). Fatty acids, antioxidants, and oxidative stress in pre-eclampsia. Int J Gynaecol Obstet.
40 Mihrshahi S, Peat JK, Webb K, et al. (2004). Effect of omega-3 fatty acid concentrations in plasma on symptoms of asthma at 18 months of age. Pediatr Allergy Immunol.
41 Mozurkewich E, Chilimigras J, Klemens C, et al. (2011). The mothers, Omega-3 and mental health study. BMC Pregnancy Childbirth.
42 Murray KE, Nyp SS. (2011). Postpartum depression. J Dev Behav Pediatr.
43 Savino F, Serraino P, Prino A, et al. (2000). Arachidonic (AA) and docosahexaenoic (DHA) acid content in healthy infants fed with an HA milk formula supplemented with LCPUFA and in breast fed infants. Adv Exp Med Biol.
44 Schindler T, Gladman L, Sinn John KH, et al. (2012). Polyunsaturated fatty acid supplementation in infancy for the prevention of allergy and food hypersensitivity. Cochrane Database of Systematic Reviews.
45 Shiraishi M, Matsuzaki M, Yatsuki Y, et al. (2015). Associations of dietary intake and plasma concentrations of eicosapentaenoic and docosahexaenoic acid with prenatal depressive symptoms in Japan. Nurs Health Sci.
46 Suzuki T. (2011). Maternal depression and child development after prenatal DHA supplementation. JAMA.
47 Thorp JM, Rice MM, Harper M, et al. (2013). Advanced lipoprotein measures and recurrent preterm birth. Am J Obstet Gynecol.
48 Thorsdottir I, Birgisdottir BE, Halldorsdottir S, et al. (2004). Association of fish and fish liver oil intake in pregnancy with infant size at birth among women of normal weight before pregnancy in a fishing community. Am J Epidemiol.
49 Tinoco SM, Sichieri R, Setta CL, et al. (2009). n-3 polyunsaturated fatty acids in milk is associate to weight gain and growth in premature infants. Lipids Health Dis.
50 Udell T, Makrides M, Gibson RA. (2003). The effect of infant diets supplemented with alpha-linolenic acid on growth and development: a systematic review and meta-analysis of randomised controlled trials. Asia Pac J Clin Nutr.
51 Verly-Miguel MVB, Farias DR, Pinto TdJP, et al. (2015). Serum docosahexaenoic acid (DHA) is inversely associated with anxiety disorders in early pregnancy. J Anxiety Disord.
52 Vik T. (2012). Early environment, early feeding, and later development: Should milk formula be supplemented with polyunsaturated fatty acids?. Dev Med Child Neurol.
53 Xiang M, Harbige LS, Zetterstrom R. (2005). Long-chain polyunsaturated fatty acids in Chinese and Swedish mothers: diet, breast milk and infant growth. Acta Paediatr.

## Population not of interest - N=37

1 Andersen AD, Michaelsen KF, Hellgren LI, et al. (2011). A randomized controlled intervention with fish oil versus sunflower oil from 9 to 18 months of age: exploring changes in growth and skinfold thicknesses. Pediatr Res.
2 Barman M, Jonsson K, Sandin A, et al. (2014). Serum fatty acid profile does not reflect seafood intake in adolescents with atopic eczema. Acta Paediatr.
3 Bolte G, Kompauer I, Fobker M, et al. (2006). Fatty acids in serum cholesteryl esters in relation to asthma and lung function in children. Clin Exp Allergy.
4 Burns JS, Dockery DW, Neas LM, et al. (2007). Low dietary nutrient intakes and respiratory health in adolescents. Chest.
5 Chatchatee P, Lee WS, Carrilho E, et al. (2014). Effects of growing-up milk supplemented with prebiotics and LCPUFAs on infections in young children. J Pediatr Gastroenterol Nutr.
6 Colter AL, Cutler C, Meckling KA. (2008). Fatty acid status and behavioural symptoms of attention deficit hyperactivity disorder in adolescents: a case-control study. Nutr J.
7 Cooper RE, Tye C, Kuntsi J, et al. (2015). Omega-3 polyunsaturated fatty acid supplementation and cognition: A systematic review and meta-analysis. Journal of Psychopharmacology.
8 de Jong C, Boehm G, Kikkert HK, et al. (2011). The Groningen LCPUFA study: No effect of short-term postnatal long-chain polyunsaturated fatty acids in healthy term infants on cardiovascular and anthropometric development at 9 years. Pediatr Res.
9 El-Ansary AK, Bacha AG, Al-Ayahdi LY. (2011). Impaired plasma phospholipids and relative amounts of essential polyunsaturated fatty acids in autistic patients from Saudi Arabia. Lipids Health Dis.
10 Engel S, Tronhjem KM, Hellgren LI, et al. (2013). Docosahexaenoic acid status at 9 months is inversely associated with communicative skills in 3-year-old girls. Matern Child Nutr.
11 Eriksson S, Mellstrom D, Strandvik B. (2009). Fatty acid pattern in serum is associated with bone mineralisation in healthy 8-year-old children. Br J Nutr.
12 Freeman MP. (2009). Complementary and alternative medicine for perinatal depression. J Affect Disord.
13 Freeman MP, Cohen LS, McInerney K. (2014). Omega-3 Fatty acids and gestational length in a high-risk psychiatric population due to psychiatric morbidity and medication exposure during pregnancy. J Clin Psychopharmacol.
14 Geppert J, Demmelmair H, Hornstra G, et al. (2008). Co-supplementation of healthy women with fish oil and evening primrose oil increases plasma docosahexaenoic acid, gamma-linolenic acid and dihomo-gamma-linolenic acid levels without reducing arachidonic acid concentrations. Br J Nutr.
15 Gow RV, Sumich A, Vallee-Tourangeau F, et al. (2013). Omega-3 fatty acids are related to abnormal emotion processing in adolescent boys with attention deficit hyperactivity disorder. Prostaglandins Leukotrienes & Essential Fatty Acids.
16 Gow RV, Vallee-Tourangeau F, Crawford MA, et al. (2013). Omega-3 fatty acids are inversely related to callous and unemotional traits in adolescent boys with attention deficit hyperactivity disorder. Prostaglandins Leukotrienes & Essential Fatty Acids.
17 Greatrex JC, Drasdo N, Dresser K. (2000). Scotopic sensitivity in dyslexia and requirements for DHA supplementation. Lancet.
18 Hoffman DR, Theuer RC, Castaneda YS, et al. (2004). Maturation of visual acuity is accelerated in breast-fed term infants fed baby food containing DHA-enriched egg yolk. J Nutr.
19 Kuratko CN, Barrett EC, Nelson EB, et al. (2013). The relationship of docosahexaenoic acid (DHA) with learning and behavior in healthy children: a review. Nutrients.
20 Li F, Jin X, Liu B, et al. (2014). Follow-up formula consumption in 3- to 4-year-olds and respiratory infections: An RCT. Pediatrics.
21 Lim Andy KH, Manley Karen J, Roberts Matthew A, et al. (2007). Fish oil for kidney transplant recipients. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd.
22 Oddy WH, de Klerk NH, Kendall GE, et al. (2004). Ratio of omega-6 to omega-3 fatty acids and childhood asthma. J Asthma.
23 Ohlund I, Hornell A, Lind T, et al. (2008). Dietary fat in infancy should be more focused on quality than on quantity. Eur J Clin Nutr.
24 Orlando MS, Dziorny AC, Harrington D, et al. (2014). Associations between prenatal and recent postnatal methylmercury exposure and auditory function at age 19 years in the Seychelles Child Development Study. Neurotoxicology and Teratology S2- Neurobehavioral Toxicology & Teratology.
25 Ortiz-Espejo M, Perez-Navero JL, Munoz-Villanueva MC, et al. (2013). Nutritional assessment in neonatal and prepubertal children with a history of extrauterine growth restriction. Early Hum Dev.
26 Portwood MM. (2006). The role of dietary fatty acids in children's behaviour and learning. Nutr Health.
27 Pulakka A, Ashorn U, Cheung YB, et al. (2015). Effect of 12-month intervention with lipid-based nutrient supplements on physical activity of 18-month-old Malawian children: A randomised, controlled trial. Eur J Clin Nutr.
28 Rudiger M, von Baehr A, Haupt R, et al. (2000). Preterm infants with high polyunsaturated fatty acid and plasmalogen content in tracheal aspirates develop bronchopulmonary dysplasia less often. Crit Care Med.
29 Rytter D, Bech BH, Halldorsson T, et al. (2013). No association between the intake of marine n-3 PUFA during the second trimester of pregnancy and factors associated with cardiometabolic risk in the 20-year-old offspring. Br J Nutr.
30 Rzehak P, Thijs C, Standl M, et al. (2010). Variants of the FADS1 FADS2 gene cluster, blood levels of polyunsaturated fatty acids and eczema in children within the first 2 years of life. PLoS ONE [Electronic Resource].
31 Scalabrin D, Stolz S, Zhuang W, et al. (2014). Impact of formula containing docosahexaenoic acid, prebiotics, and beta-glucan on allergic manifestations in young children. J Allergy Clin Immunol.
32 Scassellati C, Bonvicini C, Faraone SV, et al. (2012). Biomarkers and attention-deficit/hyperactivity disorder: A systematic review and meta-analyses. J Am Acad Child Adolesc Psychiatry.
33 Schnappinger M, Sausenthaler S, Linseisen J, et al. (2009). Fish consumption, allergic sensitisation and allergic diseases in adults. Ann Nutr Metab.
34 Schwartz J, Dube K, Sichert-Hellert W, et al. (2009). Modification of dietary polyunsaturated fatty acids via complementary food enhances n-3 long-chain polyunsaturated fatty acid synthesis in healthy infants: a double blinded randomised controlled trial. Arch Dis Child.
35 Skilton MR, Mikkila V, Wurtz P, et al. (2013). Fetal growth, omega-3 (n-3) fatty acids, and progression of subclinical atherosclerosis: preventing fetal origins of disease? The Cardiovascular Risk in Young Finns Study. Am J Clin Nutr.
36 Thienprasert A, Samuhaseneetoo S, Popplestone K, et al. (2009). Fish oil n-3 polyunsaturated fatty acids selectively affect plasma cytokines and decrease illness in Thai schoolchildren: a randomized, double-blind, placebo-controlled intervention trial. J Pediatr.
37 Tichelaar HY, Steyn NP, Nel JH, et al. (1999). Effect of catfish supplementation on the fatty acid status and growth of undernourished rural preschool children under 6 years of age: an intervention trial in Lebowa, South Africa. Asia Pac J Clin Nutr.

## Not oral intake - N=10

1 Bialecka-Pikul M, Lauterbach R, Pawlik D. (2014). May the supplementation of lipid emulsion containing DHA in VLBW infants influence their psychological development evaluated at three years of age? Preliminary study. Medycyna Wieku Rozwojowego.
2 Demirel G, Oguz SS, Celik IH, et al. (2012). The metabolic effects of two different lipid emulsions used in parenterally fed premature infants--a randomized comparative study. Early Hum Dev.
3 Lehner F, Demmelmair H, Roschinger W, et al. (2006). Metabolic effects of intravenous LCT or MCT/LCT lipid emulsions in preterm infants. J Lipid Res.
4 Pawlik D, Lauterbach R, Walczak M, et al. (2011). Docosahexaenoic acid (DHA) concentration in very low birth weight newborns receiving a fish-oil based fat emulsion from the first day of life. Preliminary clinical observation. Medycyna Wieku Rozwojowego.
5 Rodriguez A, Raederstorff D, Sarda P, et al. (2003). Preterm infant formula supplementation with alpha linolenic acid and docosahexaenoic acid. Eur J Clin Nutr.
6 Saint-Amour D, Roy MS, Bastien C, et al. (2006). Alterations of visual evoked potentials in preschool Inuit children exposed to methylmercury and polychlorinated biphenyls from a marine diet. Neurotoxicology.
7 Stark KD, Beblo S, Murthy M, et al. (2005). Alcohol consumption in pregnant, black women is associated with decreased plasma and erythrocyte docosahexaenoic acid. Alcoholism: Clinical & Experimental Research.
8 Strommen K, Blakstad EW, Moltu SJ, et al. (2014). Enhanced nutrient supply to very low birth weight infants is associated with improved white matter maturation and head growth. Neonatology.
9 Wadhwani N, Patil V, Pisal H, et al. (2014). Altered maternal proportions of long chain polyunsaturated fatty acids and their transport leads to disturbed fetal stores in preeclampsia. Prostaglandins Leukotrienes & Essential Fatty Acids.
10 Webb AN, Hardy P, Peterkin M, et al. (2008). Tolerability and safety of olive oil-based lipid emulsion in critically ill neonates: a blinded randomized trial. Nutrition.

## No outcomes of interest - N=75

1 Antonakou A, Skenderi KP, Chiou A, et al. (2013). Breast milk fat concentration and fatty acid pattern during the first six months in exclusively breastfeeding Greek women. Eur J Nutr.
2 Babin F, Rodriguez A, Sarda P, et al. (2000). Alpha linolenic acid in cholesterol esters: a marker of alphalinolenic acid intake in newborns. Eur J Clin Nutr.
3 Barden AE, Dunstan JA, Beilin LJ, et al. (2006). n -- 3 fatty acid supplementation during pregnancy in women with allergic disease: effects on blood pressure, and maternal and fetal lipids. Clin Sci.
4 Barden AE, Mori TA, Dunstan JA, et al. (2004). Fish oil supplementation in pregnancy lowers F2-isoprostanes in neonates at high risk of atopy. Free Radic Res.
5 Bisgaard H, Vissing NH, Carson CG, et al. (2013). Deep phenotyping of the unselected COPSAC2010 birth cohort study. Clin Exp Allergy.
6 Blumfield ML, Nowson C, Hure AJ, et al. (2015). Lower Protein-to-Carbohydrate Ratio in Maternal Diet is Associated with Higher Childhood Systolic Blood Pressure up to Age Four Years. Nutrients.
7 Bokor S, Koletzko B, Decsi T. (2007). Systematic review of fatty acid composition of human milk from mothers of preterm compared to full-term infants. Ann Nutr Metab.
8 Bosaeus M, Hussain A, Karlsson T, et al. (2015). A randomized longitudinal dietary intervention study during pregnancy: effects on fish intake, phospholipids, and body composition. Nutr J.
9 Bowers K, Tobias DK, Yeung E, et al. (2012). A prospective study of prepregnancy dietary fat intake and risk of gestational diabetes. Am J Clin Nutr.
10 Brenna JT, Salem N, Sinclair AJ, et al. (2009). alpha-Linolenic acid supplementation and conversion to n-3 long-chain polyunsaturated fatty acids in humans. Prostaglandins Leukot Essent Fatty Acids.
11 Brunner S, Schmid D, Huttinger K, et al. (2014). Effect of reducing the n-6/n-3 fatty acid ratio on the maternal and fetal leptin axis in relation to infant body composition. Obesity.
12 Chen X, Scholl TO, Leskiw M, et al. (2010). Differences in maternal circulating fatty acid composition and dietary fat intake in women with gestational diabetes mellitus or mild gestational hyperglycemia. Diabetes Care.
13 Choi AL, Mogensen UB, Bjerve KS, et al. (2014). Negative confounding by essential fatty acids in methylmercury neurotoxicity associations. Neurotoxicol Teratol.
14 Courage ML, McCloy UR, Herzberg GR, et al. (1998). Visual acuity development and fatty acid composition of erythrocytes in full-term infants fed breast milk, commercial formula, or evaporated milk. J Dev Behav Pediatr.
15 Dangat K, Kilari A, Mehendale S, et al. (2014). Preeclampsia alters milk neurotrophins and long chain polyunsaturated fatty acids. Int J Dev Neurosci.
16 Das UN. (2013). Polyunsaturated fatty acids and their metabolites in the pathobiology of schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry.
17 de Groot RH, Adam J, Jolles J, et al. (2004). Alpha-linolenic acid supplementation during human pregnancy does not effect cognitive functioning. Prostaglandins Leukotrienes & Essential Fatty Acids.
18 Donahue SM, Rifas-Shiman SL, Olsen SF, et al. (2009). Associations of maternal prenatal dietary intake of n-3 and n-6 fatty acids with maternal and umbilical cord blood levels. Prostaglandins Leukotrienes & Essential Fatty Acids.
19 Dunstan JA, Mitoulas LR, Dixon G, et al. (2007). The effects of fish oil supplementation in pregnancy on breast milk fatty acid composition over the course of lactation: a randomized controlled trial. Pediatr Res.
20 Dunstan JA, Mori TA, Barden A, et al. (2003). Maternal fish oil supplementation in pregnancy reduces interleukin-13 levels in cord blood of infants at high risk of atopy. Clin Exp Allergy.
21 D'Vaz N, Meldrum SJ, Dunstan JA, et al. (2012). Fish oil supplementation in early infancy modulates developing infant immune responses. Clin Exp Allergy.
22 Escolano-Margarit MV, Campoy C, Ramirez-Tortosa MC, et al. (2013). Effects of fish oil supplementation on the fatty acid profile in erythrocyte membrane and plasma phospholipids of pregnant women and their offspring: a randomised controlled trial. Br J Nutr.
23 Field CJ, Van Aerde JE, Goruk S, et al. (2010). Effect of feeding a formula supplemented with long-chain polyunsaturated fatty acids for 14 weeks improves the ex vivo response to a mitogen and reduces the response to a soy protein in infants at low risk for allergy. J Pediatr Gastroenterol Nutr.
24 Forsyth JS, Willatts P, Agostoni C, et al. (2003). Long chain polyunsaturated fatty acid supplementation in infant formula and blood pressure in later childhood: follow up of a randomised controlled trial. BMJ.
25 Franke C, Demmelmair H, Decsi T, et al. (2010). Influence of fish oil or folate supplementation on the time course of plasma redox markers during pregnancy. Br J Nutr.
26 Furuhjelm C, Jenmalm MC, Falth-Magnusson K, et al. (2011). Th1 and Th2 chemokines, vaccine-induced immunity, and allergic disease in infants after maternal -3 fatty acid supplementation during pregnancy and lactation. Pediatr Res.
27 Garcia C, Millet V, Coste TC, et al. (2011). French mothers' milk deficient in DHA contains phospholipid species of potential interest for infant development. J Pediatr Gastroenterol Nutr.
28 Garcia-Rodriguez CE, Olza J, Aguilera CM, et al. (2012). Plasma inflammatory and vascular homeostasis biomarkers increase during human pregnancy but are not affected by oily fish intake. J Nutr.
29 Ghebremeskel K, Min Y, Crawford MA, et al. (2000). Blood fatty acid composition of pregnant and nonpregnant Korean women: red cells may act as a reservoir of arachidonic acid and docosahexaenoic acid for utilization by the developing fetus. Lipids.
30 Gold DR, Willwerth BM, Tantisira KG, et al. (2006). Associations of cord blood fatty acids with lymphocyte proliferation, IL-13, and IFN-gamma. J Allergy Clin Immunol.
31 Gould JF, Makrides M, Colombo J, et al. (2014). Randomized controlled trial of maternal omega-3 long-chain PUFA supplementation during pregnancy and early childhood development of attention, working memory, and inhibitory control. Am J Clin Nutr.
32 Grandjean P, Bjerve KS, Weihe P, et al. (2001). Birthweight in a fishing community: significance of essential fatty acids and marine food contaminants. Int J Epidemiol.
33 Granot E, Jakobovich E, Rabinowitz R, et al. (2011). DHA supplementation during pregnancy and lactation affects infants' cellular but not humoral immune response. Mediators Inflamm.
34 Guerra A, Demmelmair H, Toschke AM, et al. (2007). Three-year tracking of fatty acid composition of plasma phospholipids in healthy children. Ann Nutr Metab.
35 Harper M, Li L, Zhao Y, et al. (2013). Change in mononuclear leukocyte responsiveness in midpregnancy and subsequent preterm birth. Obstet Gynecol.
36 Hawkes JS, Bryan DL, Neumann MA, et al. (2001). Transforming growth factor beta in human milk does not change in response to modest intakes of docosahexaenoic acid. Lipids.
37 Helmersson-Karlqvist J, Miles EA, Vlachava M, et al. (2012). Enhanced prostaglandin F2alpha formation in human pregnancy and the effect of increased oily fish intake: results from the Salmon in Pregnancy Study. Prostaglandins Leukotrienes & Essential Fatty Acids.
38 Hodge WG, Barnes D, Schachter HM, et al. (2006). The evidence for efficacy of omega-3 fatty acids in preventing or slowing the progression of retinitis pigmentosa: a systematic review. Can J Ophthalmol.
39 Hoppu U, Isolauri E, Koskinen P, et al. (2013). Diet and blood lipids in 1-4 year-old children. Nutrition Metabolism & Cardiovascular Diseases.
40 Jirapinyo P, Densupsoontorn N, Wiraboonchai D, et al. (2008). Fatty acid composition in breast milk from 4 regions of Thailand. J Med Assoc Thai.
41 Kennedy K, Ross S, Isaacs EB, et al. (2010). The 10-year follow-up of a randomised trial of long-chain polyunsaturated fatty acid supplementation in preterm infants: effects on growth and blood pressure. Arch Dis Child.
42 Kohlboeck G, Glaser C, Tiesler C, et al. (2011). Effect of fatty acid status in cord blood serum on children's behavioral difficulties at 10 y of age: results from the LISAplus Study. Am J Clin Nutr.
43 Krauss-Etschmann S, Hartl D, Rzehak P, et al. (2008). Decreased cord blood IL-4, IL-13, and CCR4 and increased TGF-beta levels after fish oil supplementation of pregnant women. J Allergy Clin Immunol.
44 Larnkjaer A, Hoppe C, Molgaard C, et al. (2009). The effects of whole milk and infant formula on growth and IGF-I in late infancy. Eur J Clin Nutr.
45 Larque E, Pagan A, Prieto MT, et al. (2014). Placental fatty acid transfer: a key factor in fetal growth. Ann Nutr Metab.
46 Lee HS, Barraza-Villarreal A, Hernandez-Vargas H, et al. (2013). Modulation of DNA methylation states and infant immune system by dietary supplementation with -3 PUFA during pregnancy in an intervention study. Am J Clin Nutr.
47 Lopez-Lopez A, Lopez-Sabater MC, Campoy-Folgoso C, et al. (2002). Fatty acid and sn-2 fatty acid composition in human milk from Granada (Spain) and in infant formulas. Eur J Clin Nutr.
48 Makela J, Linderborg K, Niinikoski H, et al. (2013). Breast milk fatty acid composition differs between overweight and normal weight women: the STEPS Study. Eur J Nutr.
49 Martin Alvarez E, Pena-Caballero M, Hurtado-Suazo JA, et al. (2014). Variability in adipokines profile of newborns and their mothers after DHA supplementation in pregnancy. Arch Dis Child.
50 Oken E, Guthrie LB, Bloomingdale A, et al. (2013). A pilot randomized controlled trial to promote healthful fish consumption during pregnancy: the Food for Thought Study. Nutr J.
51 Olsen SF, Hansen HS, Sorensen TI, et al. (1986). Intake of marine fat, rich in (n-3)-polyunsaturated fatty acids, may increase birthweight by prolonging gestation. Lancet.
52 Pinto TJ, Farias DR, Rebelo F, et al. (2015). Lower inter-partum interval and unhealthy life-style factors are inversely associated with n-3 essential fatty acids changes during pregnancy: a prospective cohort with Brazilian women. PLoS ONE [Electronic Resource].
53 Pivik RT, Dykman RA, Jing H, et al. (2009). Early infant diet and the omega 3 fatty acid DHA: effects on resting cardiovascular activity and behavioral development during the first half-year of life. Dev Neuropsychol.
54 Prescott SL, Barden AE, Mori TA, et al. (2007). Maternal fish oil supplementation in pregnancy modifies neonatal leukotriene production by cord-blood-derived neutrophils. Clin Sci.
55 Prescott SL, Irvine J, Dunstan JA, et al. (2007). Protein kinase Czeta: a novel protective neonatal T-cell marker that can be upregulated by allergy prevention strategies. J Allergy Clin Immunol.
56 Ramirez M, Gallardo EM, Souto AS, et al. (2001). Plasma fatty-acid composition and antioxidant capacity in low birth-weight infants fed formula enriched with n-6 and n-3 long-chain polyunsaturated fatty acids from purified phospholipids. Clin Nutr.
57 Ramon R, Ballester F, Aguinagalde X, et al. (2009). Fish consumption during pregnancy, prenatal mercury exposure, and anthropometric measures at birth in a prospective mother-infant cohort study in Spain. Am J Clin Nutr.
58 Ribeiro P, Carvalho FD, Abreu Ade A, et al. (2012). Effect of fish oil supplementation in pregnancy on the fatty acid composition of erythrocyte phospholipids and breast milk lipids. Int J Food Sci Nutr.
59 Riva E, Grandi F, Massetto N, et al. (2004). Polychlorinated biphenyls in colostral milk and visual function at 12 months of life. Acta Paediatr.
60 Romero VC, Somers EC, Stolberg V, et al. (2013). Developmental programming for allergy: a secondary analysis of the Mothers, Omega-3, and Mental Health Study. Am J Obstet Gynecol.
61 Sauerwald UC, Fink MM, Demmelmair H, et al. (2012). Effect of different levels of docosahexaenoic acid supply on fatty acid status and linoleic and alpha-linolenic acid conversion in preterm infants. J Pediatr Gastroenterol Nutr.
62 Sedlmeier EM, Brunner S, Much D, et al. (2014). Human placental transcriptome shows sexually dimorphic gene expression and responsiveness to maternal dietary n-3 long-chain polyunsaturated fatty acid intervention during pregnancy. BMC Genomics.
63 Siahanidou T, Margeli A, Lazaropoulou C, et al. (2008). Circulating adiponectin in preterm infants fed long-chain polyunsaturated fatty acids (LCPUFA)-supplemented formula--a randomized controlled study. Pediatr Res.
64 Skilton MR, Ayer JG, Harmer JA, et al. (2012). Impaired fetal growth and arterial wall thickening: a randomized trial of -3 supplementation. Pediatrics.
65 Smithers LG, Markrides M, Gibson RA. (2010). Human milk fatty acids from lactating mothers of preterm infants: a study revealing wide intra- and inter-individual variation. Prostaglandins Leukotrienes & Essential Fatty Acids.
66 Smuts CM, Borod E, Peeples JM, et al. (2003). High-DHA eggs: feasibility as a means to enhance circulating DHA in mother and infant. Lipids.
67 Steenweg-de Graaff JC, Tiemeier H, Basten MG, et al. (2015). Maternal LC-PUFA status during pregnancy and child problem behavior: the Generation R Study. Pediatr Res.
68 Steer CD, Davey Smith G, Emmett PM, et al. (2010). FADS2 polymorphisms modify the effect of breastfeeding on child IQ. PLoS One.
69 Stokes-Riner A, Thurston SW, Myers GJ, et al. (2011). Corrigendum to “A longitudinal analysis of prenatal exposure to methylmercury and fatty acids in the Seychelles”. Neurotoxicol Teratol.
70 Storck Lindholm E, Strandvik B, Altman D, et al. (2013). Different fatty acid pattern in breast milk of obese compared to normal-weight mothers. Prostaglandins Leukotrienes & Essential Fatty Acids.
71 Storro O, Oien T, Dotterud CK, et al. (2010). A primary health-care intervention on pre- and postnatal risk factor behavior to prevent childhood allergy. The Prevention of Allergy among Children in Trondheim (PACT) study. BMC Public Health.
72 Vivatvakin B, Mahayosnond A, Theamboonlers A, et al. (2010). Effect of a whey-predominant starter formula containing LCPUFAs and oligosaccharides (FOS/GOS) on gastrointestinal comfort in infants. Asia Pac J Clin Nutr.
73 Warstedt K, Furuhjelm C, Duchen K, et al. (2009). The effects of omega-3 fatty acid supplementation in pregnancy on maternal eicosanoid, cytokine, and chemokine secretion. Pediatr Res.
74 West AA, Yan J, Jiang X, et al. (2013). Choline intake influences phosphatidylcholine DHA enrichment in nonpregnant women but not in pregnant women in the third trimester. Am J Clin Nutr.
75 Zhang L. (1997). The effects of essential fatty acids preparation in the treatment of intrauterine growth retardation. Am J Perinatol.

## Does not address a KQ - N=2

1 Belfort MB, Rifas-Shiman SL, Sullivan T, et al. (2011). Infant growth before and after term: effects on neurodevelopment in preterm infants. Pediatrics.
2 van Gool CJ, Thijs C, Dagnelie PC, et al. (2004). Determinants of neonatal IgE level: parity, maternal age, birth season and perinatal essential fatty acid status in infants of atopic mothers. Allergy.

## Only exposure/intervention was total fish intake - N=14

1 Drouillet P, Kaminski M, De Lauzon-Guillain B, et al. (2009). Association between maternal seafood consumption before pregnancy and fetal growth: evidence for an association in overweight women. The EDEN mother-child cohort. Paediatr Perinat Epidemiol.
2 Fereidooni B, Jenabi E. (2014). The use of omega 3 on pregnancy outcomes: a single-center study. JPMA - Journal of the Pakistan Medical Association.
3 Gale CR, Robinson SM, Godfrey KM, et al. (2008). Oily fish intake during pregnancy--association with lower hyperactivity but not with higher full-scale IQ in offspring. J Child Psychol Psychiatry.
4 Leventakou V, Roumeliotaki T, Martinez D, et al. (2014). Fish intake during pregnancy, fetal growth, and gestational length in 19 European birth cohort studies. Am J Clin Nutr.
5 Luxwolda MF, Kuipers RS, Sango WS, et al. (2012). A maternal erythrocyte DHA content of approximately 6 g% is the DHA status at which intrauterine DHA biomagnifications turns into bioattenuation and postnatal infant DHA equilibrium is reached. Eur J Nutr.
6 Lv N, Xiao L, Ma J. (2014). Dietary pattern and asthma: a systematic review and meta-analysis. J Asthma Allergy.
7 Magnusson J, Kull I, Rosenlund H, et al. (2013). Fish consumption in infancy and development of allergic disease up to age 12 y. Am J Clin Nutr.
8 Maslova E, Strom M, Oken E, et al. (2013). Fish intake during pregnancy and the risk of child asthma and allergic rhinitis - longitudinal evidence from the Danish National Birth Cohort. Br J Nutr.
9 Nafstad P, Nystad W, Magnus P, et al. (2003). Asthma and allergic rhinitis at 4 years of age in relation to fish consumption in infancy. J Asthma.
10 Oien T, Storro O, Johnsen R. (2010). Do early intake of fish and fish oil protect against eczema and doctor-diagnosed asthma at 2 years of age? A cohort study. J Epidemiol Community Health.
11 Oken E, Osterdal ML, Gillman MW, et al. (2008). Associations of maternal fish intake during pregnancy and breastfeeding duration with attainment of developmental milestones in early childhood: a study from the Danish National Birth Cohort. Am J Clin Nutr.
12 Olsen SF, Secher NJ. (2002). Low consumption of seafood in early pregnancy as a risk factor for preterm delivery: prospective cohort study. BMJ.
13 Rossary A, Farges MC, Lamas B, et al. (2014). Increased consumption of salmon during pregnancy partly prevents the decline of some plasma essential amino acid concentrations in pregnant women. Clin Nutr.
14 Sagiv SK, Thurston SW, Bellinger DC, et al. (2012). Prenatal exposure to mercury and fish consumption during pregnancy and attention-deficit/hyperactivity disorder-related behavior in children. Arch Pediatr Adolesc Med.

## Biomarkers only - N=39

1 Bascunan KA, Valenzuela R, Chamorro R, et al. (2014). Polyunsaturated fatty acid composition of maternal diet and erythrocyte phospholipid status in Chilean pregnant women. Nutrients.
2 Bergmann RL, Haschke-Becher E, Klassen-Wigger P, et al. (2008). Supplementation with 200 mg/day docosahexaenoic acid from mid-pregnancy through lactation improves the docosahexaenoic acid status of mothers with a habitually low fish intake and of their infants. Ann Nutr Metab.
3 Berseth CL, Harris CL, Wampler JL, et al. (2014). Liquid human milk fortifier significantly improves docosahexaenoic and arachidonic acid status in preterm infants. Prostaglandins Leukotrienes & Essential Fatty Acids.
4 Boris J, Jensen B, Salvig JD, et al. (2004). A randomized controlled trial of the effect of fish oil supplementation in late pregnancy and early lactation on the n-3 fatty acid content in human breast milk. Lipids.
5 Carnielli VP, Simonato M, Verlato G, et al. (2007). Synthesis of long-chain polyunsaturated fatty acids in preterm newborns fed formula with long-chain polyunsaturated fatty acids. Am J Clin Nutr.
6 Clandinin MT, Aerde Jv, Parrott A, et al. (1999). Assessment of feeding different amounts of arachidonic and docosahexaenoic acids in preterm infant formulas on the fatty acid content of lipoprotein lipids. Acta Paediatr.
7 Clandinin MT, Aerde Jv, Parrott A, et al. (1997). Assessment of the efficacious dose of arachidonic and docosahexaenoic acids in preterm infant formulas: fatty acid composition of erythrocyte membrane lipids. Pediatr Res.
8 Courville AB, Keplinger MR, Judge MP, et al. (2009). Plasma or red blood cell phospholipids can be used to assess docosahexaenoic acid status in women during pregnancy. Nutr Res.
9 De Vriese SR, Dhont M, Christophe AB. (2003). FA composition of cholesteryl esters and phospholipids in maternal plasma during pregnancy and at delivery and in cord plasma at birth. Lipids.
10 Decsi T, Campoy C, Koletzko B. (2005). Effect of N-3 polyunsaturated fatty acid supplementation in pregnancy: the Nuheal trial. Adv Exp Med Biol.
11 Decsi T, Kelemen B, Minda H, et al. (2000). Effect of type of early infant feeding on fatty acid composition of plasma lipid classes in full-term infants during the second 6 months of life. J Pediatr Gastroenterol Nutr.
12 Dunstan JA, Mori TA, Barden A, et al. (2004). Effects of n-3 polyunsaturated fatty acid supplementation in pregnancy on maternal and fetal erythrocyte fatty acid composition. Eur J Clin Nutr.
13 Dunstan JA, Roper J, Mitoulas L, et al. (2004). The effect of supplementation with fish oil during pregnancy on breast milk immunoglobulin A, soluble CD14, cytokine levels and fatty acid composition. Clin Exp Allergy.
14 Friesen RW, Innis SM. (2010). Linoleic acid is associated with lower long-chain n-6 and n-3 fatty acids in red blood cell lipids of Canadian pregnant women. Am J Clin Nutr.
15 Garcia-Rodriguez CE, Mesa MD, Olza J, et al. (2012). Does consumption of two portions of salmon per week enhance the antioxidant defense system in pregnant women?. Antioxidants & Redox Signaling.
16 Hansen IB, Friis-Hansen B, Clausen J. (1969). The fatty acid composition of umbilical cord serum, infant serum and maternal serum and its relation to the diet. Z Ernahrungswiss.
17 Helland IB, Saugstad OD, Saarem K, et al. (2006). Supplementation of n-3 fatty acids during pregnancy and lactation reduces maternal plasma lipid levels and provides DHA to the infants. J Matern Fetal Neonatal Med.
18 Hoffman DR, Wheaton DK, James KJ, et al. (2006). Docosahexaenoic acid in red blood cells of term infants receiving two levels of long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr.
19 Imhoff-Kunsch B, Stein AD, Villalpando S, et al. (2011). Docosahexaenoic acid supplementation from mid-pregnancy to parturition influenced breast milk fatty acid concentrations at 1 month postpartum in Mexican women. J Nutr.
20 Innis SM, Elias SL. (2003). Intakes of essential n-6 and n-3 polyunsaturated fatty acids among pregnant Canadian women. Am J Clin Nutr.
21 Kaempf-Rotzoll DE, Hellstern G, Linderkamp O. (2003). Influence of long-chain polyunsaturated fatty acid formula feeds on vitamin E status in preterm infants. Int J Vitam Nutr Res.
22 Krauss-Etschmann S, Shadid R, Campoy C, et al. (2007). Effects of fish-oil and folate supplementation of pregnant women on maternal and fetal plasma concentrations of docosahexaenoic acid and eicosapentaenoic acid: a European randomized multicenter trial. Am J Clin Nutr.
23 Lapillonne A, Brossard N, Claris O, et al. (2000). Erythrocyte fatty acid composition in term infants fed human milk or a formula enriched with a low eicosapentanoic acid fish oil for 4 months. Eur J Pediatr.
24 Lapillonne A, Picaud JC, Chirouze V, et al. (2000). The use of low-EPA fish oil for long-chain polyunsaturated fatty acid supplementation of preterm infants. Pediatr Res.
25 Marc I, Plourde M, Lucas M, et al. (2011). Early docosahexaenoic acid supplementation of mothers during lactation leads to high plasma concentrations in very preterm infants. J Nutr.
26 Montgomery C, Speake BK, Cameron A, et al. (2003). Maternal docosahexaenoic acid supplementation and fetal accretion. Br J Nutr.
27 Moya M, Cortes E, Juste M, et al. (2001). Fatty acid absorption in preterms on formulas with and without long-chain polyunsaturated fatty acids and in terms on formulas without these added. Eur J Clin Nutr.
28 Muhlhausler BS, Gibson RA, Yelland LN, et al. (2014). Heterogeneity in cord blood DHA concentration: Towards an explanation. Prostaglandins Leukotrienes & Essential Fatty Acids.
29 Niinivirta K, Laakso P, Linderborg K, et al. (2014). Maternal dietary counseling during pregnancy and infant fatty acid profiles. Int J Food Sci Nutr.
30 Otto SJ, van Houwelingen AC, Badart-Smook A, et al. (2001). Changes in the maternal essential fatty acid profile during early pregnancy and the relation of the profile to diet. Am J Clin Nutr.
31 Otto SJ, van Houwelingen AC, Badart-Smook A, et al. (2001). Comparison of the peripartum and postpartum phospholipid polyunsaturated fatty acid profiles of lactating and nonlactating women. Am J Clin Nutr.
32 Peng Y, Zhou T, Wang Q, et al. (2009). Fatty acid composition of diet, cord blood and breast milk in Chinese mothers with different dietary habits. Prostaglandins Leukotrienes & Essential Fatty Acids.
33 Sabel KG, Lundqvist-Persson C, Bona E, et al. (2009). Fatty acid patterns early after premature birth, simultaneously analysed in mothers' food, breast milk and serum phospholipids of mothers and infants. Lipids Health Dis.
34 Sala-Vila A, Campoy C, Castellote AI, et al. (2006). Influence of dietary source of docosahexaenoic and arachidonic acids on their incorporation into membrane phospholipids of red blood cells in term infants. Prostaglandins Leukotrienes & Essential Fatty Acids.
35 Sanjurjo P, Ruiz-Sanz JI, Jimeno P, et al. (2004). Supplementation with docosahexaenoic acid in the last trimester of pregnancy: maternal-fetal biochemical findings. J Perinat Med.
36 Smithers LG, Gibson RA, McPhee A, et al. (2008). Effect of two doses of docosahexaenoic acid (DHA) in the diet of preterm infants on infant fatty acid status: results from the DINO trial. Prostaglandins Leukotrienes & Essential Fatty Acids.
37 Stark KD, Beblo S, Murthy M, et al. (2005). Comparison of bloodstream fatty acid composition from African-American women at gestation, delivery, and postpartum. J Lipid Res.
38 Valentine CJ, Morrow G, Pennell M, et al. (2013). Randomized controlled trial of docosahexaenoic acid supplementation in midwestern U.S. human milk donors. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine.
39 Vlaardingerbroek H, Hornstra G. (2004). Essential fatty acids in erythrocyte phospholipids during pregnancy and at delivery in mothers and their neonates: comparison with plasma phospholipids. Prostaglandins Leukotrienes & Essential Fatty Acids.

## Duplicate data - N=24

1 Denburg JA, Hatfield HM, Cyr MM, et al. (2005). Fish oil supplementation in pregnancy modifies neonatal progenitors at birth in infants at risk of atopy. Pediatr Res.
2 Drover J, Hoffman DR, Castañeda YS, et al. (2009). Three randomized controlled trials of early long-chain polyunsaturated fatty acid supplementation on means-end problem solving in 9-month-olds. Child Dev.
3 Drover JR, Felius J, Hoffman DR, et al. (2012). A randomized trial of DHA intake during infancy: School readiness and receptive vocabulary at 2–3 5 years of age. Early Hum Dev.
4 Duley L. (2008). Pre-eclampsia, eclampsia, and hypertension. Clin Evid.
5 Hernandez E, Barraza-Villarreal A, Escamilla-Nunez MC, et al. (2013). Prenatal determinants of cord blood total immunoglobulin E levels in Mexican newborns. Allergy Asthma Proc.
6 Lee HS, Barraza-Villarreal A, Biessy C, et al. (2014). Dietary supplementation with polyunsaturated fatty acid during pregnancy modulates DNA methylation at IGF2/H19 imprinted genes and growth of infants. Physiol Genomics.
7 Lumia M, Luukkainen P, Kaila M, et al. (2012). Maternal dietary fat and fatty acid intake during lactation and the risk of asthma in the offspring. Acta Paediatr.
8 Makrides M. (2013). DHA supplementation during the perinatal period and neurodevelopment: Do some babies benefit more than others?. Prostaglandins Leukotrienes & Essential Fatty Acids.
9 Makrides M, Neumann MA, Gibson RA. (2001). Perinatal characteristics may influence the outcome of visual acuity. Lipids.
10 Markhus MW, Skotheim S, Graff IE, et al. (2013). Low omega-3 index in pregnancy is a possible biological risk factor for postpartum depression. PLoS One.
11 Mattes E, McCarthy S, Gong G, et al. (2009). Maternal mood scores in mid-pregnancy are related to aspects of neonatal immune function. Brain Behav Immun.
12 Mattes E, McCarthy S, Gong G, et al. (2009). Maternal mood scores in mid-pregnancy are related to aspects of neonatal immune function. Brain Behav Immun.
13 Mihrshahi S, Peat JK, Marks GB, et al. (2003). Eighteen-month outcomes of house dust mite avoidance and dietary fatty acid modification in the Childhood Asthma Prevention Study (CAPS). J Allergy Clin Immunol.
14 Miyake Y, Sasaki S, Yokoyama T, et al. (2006). Risk of postpartum depression in relation to dietary fish and fat intake in Japan: the Osaka Maternal and Child Health Study. Psychol Med.
15 Olsen SF, Osterdal ML, Salvig JD, et al. (2007). Duration of pregnancy in relation to fish oil supplementation and habitual fish intake: a randomised clinical trial with fish oil. Eur J Clin Nutr.
16 Owen C, Rees A-M, Parker G. (2008). The role of fatty acids in the development and treatment of mood disorders. Current Opinion in Psychiatry.
17 Simmer K. (2000). Long-chain polyunsaturated fatty acid supplementation in infants born at term. Cochrane Database of Systematic Reviews.
18 Simmer K. (2000). Long-chain polyunsaturated fatty acid supplementation in preterm infants. Cochrane Database of Systematic Reviews.
19 Simmer K. (2001). Long-chain polyunsaturated fatty acid supplementation in infants born at term. Cochrane Database of Systematic Reviews.
20 Simmer K, Patole S. (2004). Longchain polyunsaturated fatty acid supplementation in preterm infants. Cochrane Database of Systematic Reviews.
21 Simmer K, Patole SK, Rao SC. (2008). Long-chain polyunsaturated fatty acid supplementation in infants born at term. Cochrane Database of Systematic Reviews.
22 Simmer K, Schulzke SM, Patole S. (2008). Long-chain polyunsaturated fatty acid supplementation in preterm infants. Cochrane Database of Systematic Reviews.
23 van de Lagemaat M, Rotteveel J, Muskiet FA, et al. (2011). Post term dietary-induced changes in DHA and AA status relate to gains in weight, length, and head circumference in preterm infants. Prostaglandins Leukotrienes & Essential Fatty Acids.
24 van Goor SA, Dijck-Brouwer DA, Erwich JJ, et al. (2011). The influence of supplemental docosahexaenoic and arachidonic acids during pregnancy and lactation on neurodevelopment at eighteen months. Prostaglandins Leukotrienes & Essential Fatty Acids.

## No interventions of interest - N=7

1 Almqvist C, Garden F, Xuan W, et al. (2007). Omega-3 and omega-6 fatty acid exposure from early life does not affect atopy and asthma at age 5 years. J Allergy Clin Immunol.
2 Ashorn P, Alho L, Ashorn U, et al. (2015). Supplementation of Maternal Diets during Pregnancy and for 6 Months Postpartum and Infant Diets Thereafter with Small-Quantity Lipid-Based Nutrient Supplements Does Not Promote Child Growth by 18 Months of Age in Rural Malawi: A Randomized Controlled Trial. J Nutr.
3 Ashorn P, Alho L, Ashorn U, et al. (2015). The impact of lipid-based nutrient supplement provision to pregnant women on newborn size in rural Malawi: A randomized controlled trial. Am J Clin Nutr.
4 Burks W, Jones SM, Berseth CL, et al. (2008). Hypoallergenicity and effects on growth and tolerance of a new amino acid-based formula with docosahexaenoic acid and arachidonic acid. J Pediatr.
5 Gibson RA, Barclay D, Marshall H, et al. (2009). Safety of supplementing infant formula with long-chain polyunsaturated fatty acids and Bifidobacterium lactis in term infants: a randomised controlled trial. Br J Nutr.
6 Mardones F, Urrutia MT, Villarroel L, et al. (2008). Effects of a dairy product fortified with multiple micronutrients and omega-3 fatty acids on birth weight and gestation duration in pregnant Chilean women. Public Health Nutr.
7 van der Merwe LF, Moore SE, Fulford AJ, et al. (2013). Long-chain PUFA supplementation in rural African infants: a randomized controlled trial of effects on gut integrity, growth, and cognitive development. Am J Clin Nutr.

## Non-Systematic Review Background - N=58

1 Batchelor JM, Grindlay DJ, Williams HC. (2010). What's new in atopic eczema? An analysis of systematic reviews published in 2008 and 2009. Clin Exp Dermatol.
2 Borja-Hart NL, Marino J. (2010). Role of omega-3 Fatty acids for prevention or treatment of perinatal depression. Pharmacotherapy:The Journal of Human Pharmacology & Drug Therapy.
3 Carvajal JA. (2014). Docosahexaenoic acid supplementation early in pregnancy may prevent deep placentation disorders. BioMed Research International.
4 Casper RC. (2004). Nutrients, neurodevelopment, and mood. Current Psychiatry Reports.
5 Cheatham CL, Colombo J, Carlson SE. (2006). N-3 fatty acids and cognitive and visual acuity development: methodologic and conceptual considerations. Am J Clin Nutr.
6 Ciaccio CE, Girdhar M. (2014). Effect of maternal omega3 fatty acid supplementation on infant allergy. Ann Allergy Asthma Immunol.
7 Cohen JT, Bellinger DC, Connor WE, et al. (2005). A quantitative analysis of prenatal intake of n-3 polyunsaturated fatty acids and cognitive development. Am J Prev Med.
8 Decsi T. (2009). Effects of supplementing LCPUFA to the diet of pregnant women: data from RCT. Adv Exp Med Biol.
9 Decsi T, Koletzko B. (2005). N-3 fatty acids and pregnancy outcomes. Curr Opin Clin Nutr Metab Care.
10 Duchen K, Bjorksten B. (2001). Polyunsaturated n-3 fatty acids and the development of atopic disease. Lipids.
11 (2014). EFSA NDA Panel (EFSA Panel on Dietetic Products NaA. Scientific Opinion on health benefits of seafood (fish and shellfish) consumption in relation to health risks associated with exposure to methylmercury. EFSA Journal.
12 Facchinetti F, Fazzio M, Venturini P. (2005). Polyunsaturated fatty acids and risk of preterm delivery. Eur Rev Med Pharmacol Sci.
13 Fleith M, Clandinin MT. (2005). Dietary PUFA for preterm and term infants: review of clinical studies. Crit Rev Food Sci Nutr.
14 Forsyth JS, Carlson SE. (2001). Long-chain polyunsaturated fatty acids in infant nutrition: effects on infant development. Curr Opin Clin Nutr Metab Care.
15 Grieger JA, Clifton VL. (2015). A review of the impact of dietary intakes in human pregnancy on infant birthweight. Nutrients.
16 Hadders-Algra M. (2005). The role of long-chain polyunsaturated fatty acids (LCPUFA) in growth and development. Adv Exp Med Biol.
17 Hadders-Algra M. (2011). Prenatal and early postnatal supplementation with long-chain polyunsaturated fatty acids: neurodevelopmental considerations. Am J Clin Nutr.
18 Hadders-Algra M, Bouwstra H, van Goor SA, et al. (2007). Prenatal and early postnatal fatty acid status and neurodevelopmental outcome. J Perinat Med.
19 Hoffman DR, Boettcher JA, Diersen-Schade DA. (2009). Toward optimizing vision and cognition in term infants by dietary docosahexaenoic and arachidonic acid supplementation: a review of randomized controlled trials. Prostaglandins Leukotrienes & Essential Fatty Acids.
20 Hosli I, Zanetti-Daellenbach R, Holzgreve W, et al. (2007). Role of omega 3-fatty acids and multivitamins in gestation. J Perinat Med.
21 Jensen CL, Lapillonne A. (2009). Docosahexaenoic acid and lactation. Prostaglandins Leukotrienes & Essential Fatty Acids.
22 Kim DR, Epperson CN, Weiss AR, et al. (2014). Pharmacotherapy of postpartum depression: an update. Expert Opin Pharmacother.
23 Koletzko B, Boey CC, Campoy C, et al. (2014). Current information and Asian perspectives on long-chain polyunsaturated fatty acids in pregnancy, lactation, and infancy: systematic review and practice recommendations from an early nutrition academy workshop. Ann Nutr Metab.
24 Koletzko B, Cetin I, Brenna JT, et al. (2007). Dietary fat intakes for pregnant and lactating women. Br J Nutr.
25 Koren G. (2015). Polyunsaturated fatty acids and fetal brain development. Can Fam Physician.
26 Lapillonne A, Carlson SE. (2001). Polyunsaturated fatty acids and infant growth. Lipids.
27 Larque E, Demmelmair H, Koletzko B. (2002). Perinatal supply and metabolism of long-chain polyunsaturated fatty acids: importance for the early development of the nervous system. Ann N Y Acad Sci.
28 Makrides M. (2009). Is there a dietary requirement for DHA in pregnancy?. Prostaglandins Leukotrienes & Essential Fatty Acids.
29 Makrides M, Anderson A, Gibson RA. (2013). Early influences of nutrition on fetal growth. Nestle Nutr Inst Workshop Ser.
30 Makrides M, Smithers LG, Gibson RA. (2010). Role of long-chain polyunsaturated fatty acids in neurodevelopment and growth. Nestle Nutrition Workshop Series. Paediatric Programme.
31 Marini A, Vegni C, Gangi S, et al. (2003). Influence of different types of post-discharge feeding on somatic growth, cognitive development and their correlation in very low birthweight preterm infants. Acta Paediatrica Supplement.
32 Meldrum SJ, Smith MA, Prescott SL, et al. (2011). Achieving definitive results in long-chain polyunsaturated fatty acid supplementation trials of term infants: factors for consideration. Nutr Rev.
33 Michaelsen KF, Larnkjaer A, Lauritzen L, et al. (2010). Science base of complementary feeding practice in infancy. Curr Opin Clin Nutr Metab Care.
34 Morse N. (2015). Health benefits of maternal supplementation with docosahexaenoic acid, folic acid, vitamin D and iodine during pregnancy and lactation for foetal and infant brain development and function. Lipid Technology.
35 Morse NL. (2012). Benefits of docosahexaenoic acid, folic acid, vitamin D and iodine on foetal and infant brain development and function following maternal supplementation during pregnancy and lactation. Nutrients.
36 Mozurkewich EL, Klemens C. (2012). Omega-3 fatty acids and pregnancy: current implications for practice. Curr Opin Obstet Gynecol.
37 Oh R. (2005). Practical applications of fish oil (Omega-3 fatty acids) in primary care. J Am Board Fam Pract.
38 Olsen SF. (2004). Is supplementation with marine omega-3 fatty acids during pregnancy a useful tool in the prevention of preterm birth?. Clin Obstet Gynecol.
39 Olsen SF, Secher NJ. (1990). A possible preventive effect of low-dose fish oil on early delivery and pre-eclampsia: indications from a 50-year-old controlled trial. Br J Nutr.
40 Owen C, Rees AM, Parker G. (2008). The role of fatty acids in the development and treatment of mood disorders. Current Opinion in Psychiatry.
41 Protzko J, Aronson J, Blair C. (2013). How to make a young child smarter: Evidence from the Database of Raising Intelligence. Perspect Psychol Sci.
42 Ramakrishnan U, Imhoff-Kunsch B, DiGirolamo AM. (2009). Role of docosahexaenoic acid in maternal and child mental health. Am J Clin Nutr.
43 Richardson AJ. (2006). Omega-3 fatty acids in ADHD and related neurodevelopmental disorders. Int Rev Psychiatry.
44 Riediger ND, Othman RA, Suh M, et al. (2009). A systemic review of the roles of n-3 fatty acids in health and disease. J Am Diet Assoc.
45 Schuchardt JP, Huss M, Stauss-Grabo M, et al. (2010). Significance of long-chain polyunsaturated fatty acids (PUFAs) for the development and behaviour of children. Eur J Pediatr.
46 Secher NJ. (2007). Does fish oil prevent preterm birth?. J Perinat Med.
47 Shams K, Grindlay DJ, Williams HC. (2011). What's new in atopic eczema? An analysis of systematic reviews published in 2009-2010. Clin Exp Dermatol.
48 Shapiro GD, Fraser WD, Séguin JR. (2012). Emerging risk factors for postpartum depression: Serotonin transporter genotype an omega-3 fatty acid status. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie.
49 Shoji H, Koletzko B. (2007). Oxidative stress and antioxidant protection in the perinatal period. Curr Opin Clin Nutr Metab Care.
50 Sinn N. (2008). Nutritional and dietary influences on attention deficit hyperactivity disorder. Nutr Rev.
51 Sinn N, Milte C, Howe PR. (2010). Oiling the brain: a review of randomized controlled trials of omega-3 fatty acids in psychopathology across the lifespan. Nutrients.
52 Szajewska H, Makrides M. (2011). Is early nutrition related to short-term health and long-term outcome?. Ann Nutr Metab.
53 Tai EK, Wang XB, Chen ZY. (2013). An update on adding docosahexaenoic acid (DHA) and arachidonic acid (AA) to baby formula. Food Funct.
54 Torley D, Futamura M, Williams HC, et al. (2013). What's new in atopic eczema? An analysis of systematic reviews published in 2010-11. Clin Exp Dermatol.
55 Uauy R, Hoffman DR. (2000). Essential fat requirements of preterm infants. Am J Clin Nutr.
56 Villar J, Merialdi M, Gulmezoglu AM, et al. (2003). Nutritional interventions during pregnancy for the prevention or treatment of maternal morbidity and preterm delivery: an overview of randomized controlled trials. J Nutr.
57 Willatts P, Forsyth JS. (2000). The role of long-chain polyunsaturated fatty acids in infant cognitive development. Prostaglandins Leukotrienes & Essential Fatty Acids.
58 Wroble M, Mash C, Williams L, et al. (2002). Should long chain polyunsaturated fatty acids be added to infant formula to promote development?. J Appl Dev Psychol.

## Systematic reviews - N=44

1 Anandan C, Nurmatov U, Sheikh A. (2009). Omega 3 and 6 oils for primary prevention of allergic disease: systematic review and meta-analysis. Allergy.
2 Beyerlein A, Hadders-Algra M, Kennedy K, et al. (2010). Infant formula supplementation with long-chain polyunsaturated fatty acids has no effect on Bayley developmental scores at 18 months of age--IPD meta-analysis of 4 large clinical trials. J Pediatr Gastroenterol Nutr.
3 Campoy C, Escolano-Margarit MV, Anjos T, et al. (2012). Omega 3 fatty acids on child growth, visual acuity and neurodevelopment. Br J Nutr.
4 Chen B, Ji X, Zhang L, et al. (2015). Fish Oil Supplementation does not Reduce Risks of Gestational Diabetes Mellitus, Pregnancy-Induced Hypertension, or Pre-Eclampsia: A Meta-Analysis of Randomized Controlled Trials. Med Sci Monit.
5 Delgado-Noguera MF, Calvache JA, Bonfill Cosp X. (2010). Supplementation with long chain polyunsaturated fatty acids (LCPUFA) to breastfeeding mothers for improving child growth and development. Cochrane Database of Systematic Reviews.
6 Delgado-Noguera MF, Calvache JA, Bonfill Cosp X, et al. (2015). Supplementation with long chain polyunsaturated fatty acids (LCPUFA) to breastfeeding mothers for improving child growth and development. Cochrane Database of Systematic Reviews.
7 Dennis CL. (2004). Preventing postpartum depression part I: a review of biological interventions. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie.
8 Dennis C-LE. (2004). Preventing Postpartum Depression Part I: A Review of Biological Interventions. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie.
9 Duley L. (2011). Pre-eclampsia, eclampsia, and hypertension. Clin Evid.
10 Dunlop AL, Kramer MR, Hogue CJ, et al. (2011). Racial disparities in preterm birth: an overview of the potential role of nutrient deficiencies. Acta Obstet Gynecol Scand.
11 Eilander A, Hundscheid DC, Osendarp SJ, et al. (2007). Effects of n-3 long chain polyunsaturated fatty acid supplementation on visual and cognitive development throughout childhood: a review of human studies. Prostaglandins Leukotrienes & Essential Fatty Acids.
12 Gibson RA, Chen W, Makrides M. (2001). Randomized trials with polyunsaturated fatty acid interventions in preterm and term infants: functional and clinical outcomes. Lipids.
13 Gunaratne AW, Makrides M, Collins CT. (2015). Maternal prenatal and/or postnatal n-3 long chain polyunsaturated fatty acids (LCPUFA) supplementation for preventing allergies in early childhood. Cochrane Database of Systematic Reviews.
14 Honest H, Forbes CA, Duree KH, et al. (2009). Screening to prevent spontaneous preterm birth: systematic reviews of accuracy and effectiveness literature with economic modelling. Health Technology Assessment (Winchester, England).
15 Horvath A, Koletzko B, Szajewska H. (2007). Effect of supplementation of women in high-risk pregnancies with long-chain polyunsaturated fatty acids on pregnancy outcomes and growth measures at birth: a meta-analysis of randomized controlled trials. Br J Nutr.
16 Imhoff-Kunsch B, Briggs V, Goldenberg T, et al. (2012). Effect of n-3 long-chain polyunsaturated fatty acid intake during pregnancy on maternal, infant, and child health outcomes: a systematic review. Paediatr Perinat Epidemiol.
17 Jans LA, Giltay EJ, Van der Does AJ. (2010). The efficacy of n-3 fatty acids DHA and EPA (fish oil) for perinatal depression. Br J Nutr.
18 Jiao J, Li Q, Chu J, et al. (2014). Effect of n-3 PUFA supplementation on cognitive function throughout the life span from infancy to old age: a systematic review and meta-analysis of randomized controlled trials. Am J Clin Nutr.
19 Klemens CM, Berman DR, Mozurkewich EL. (2011). The effect of perinatal omega-3 fatty acid supplementation on inflammatory markers and allergic diseases: a systematic review. BJOG.
20 Leung BM, Wiens KP, Kaplan BJ. (2011). Does prenatal micronutrient supplementation improve children's mental development? A systematic review. BMC Pregnancy Childbirth.
21 Lo A, Sienna J, Mamak E, et al. (2012). The effects of maternal supplementation of polyunsaturated Fatty acids on visual, neurobehavioural, and developmental outcomes of the child: a systematic review of the randomized trials. Obstet Gynecol Int.
22 Makrides M, Duley L, Olsen SF. (2006). Marine oil, and other prostaglandin precursor, supplementation for pregnancy uncomplicated by pre-eclampsia or intrauterine growth restriction. Cochrane Database of Systematic Reviews.
23 Makrides M, Gibson RA, Udell T, et al. (2005). Supplementation of infant formula with long-chain polyunsaturated fatty acids does not influence the growth of term infants. Am J Clin Nutr.
24 Martinez-Victoria E, Yago MD. (2012). Omega 3 polyunsaturated fatty acids and body weight. Br J Nutr.
25 Miller BJ, Murray L, Beckmann MM, et al. (2013). Dietary supplements for preventing postnatal depression. Cochrane Database of Systematic Reviews.
26 Ortega RM, Rodriguez-Rodriguez E, Lopez-Sobaler AM. (2012). Effects of omega 3 fatty acids supplementation in behavior and non-neurodegenerative neuropsychiatric disorders. Br J Nutr.
27 Previti G, Pawlby S, Chowdhury S, et al. (2014). Neurodevelopmental outcome for offspring of women treated for antenatal depression: a systematic review. Archives of Women's Mental Health.
28 Qawasmi A, Landeros-Weisenberger A, Bloch MH. (2013). Meta-analysis of LCPUFA supplementation of infant formula and visual acuity. Pediatrics.
29 Qawasmi A, Landeros-Weisenberger A, Leckman JF, et al. (2012). Meta-analysis of long-chain polyunsaturated fatty acid supplementation of formula and infant cognition. Pediatrics.
30 Rosenfeld E, Beyerlein A, Hadders-Algra M, et al. (2009). IPD meta-analysis shows no effect of LC-PUFA supplementation on infant growth at 18 months. Acta Paediatr.
31 Saccone G, Berghella V. (2015). Omega-3 supplementation to prevent recurrent preterm birth: a systematic review and metaanalysis of randomized controlled trials. Am J Obstet Gynecol.
32 Saccone G, Berghella V. (2015). Omega-3 long chain polyunsaturated fatty acids to prevent preterm birth: a systematic review and meta-analysis. Obstet Gynecol.
33 Salvig JD, Lamont RF. (2011). Evidence regarding an effect of marine n-3 fatty acids on preterm birth: a systematic review and meta-analysis. Acta Obstet Gynecol Scand.
34 SanGiovanni JP, Berkey CS, Dwyer JT, et al. (2000). Dietary essential fatty acids, long-chain polyunsaturated fatty acids, and visual resolution acuity in healthy fullterm infants: a systematic review. Early Hum Dev.
35 Schachter HM, Reisman J, Tran K, et al. (2004). Health effects of omega-3 fatty acids on asthma. Evidence Report: Technology Assessment (Summary).
36 Schulzke SM, Patole SK, Simmer K. (2011). Long-chain polyunsaturated fatty acid supplementation in preterm infants. Cochrane Database of Systematic Reviews.
37 Simmer K, Patole SK, Rao SC. (2011). Long-chain polyunsaturated fatty acid supplementation in infants born at term. Cochrane Database of Systematic Reviews.
38 Smithers LG, Gibson RA, McPhee A, et al. (2008). Effect of long-chain polyunsaturated fatty acid supplementation of preterm infants on disease risk and neurodevelopment: a systematic review of randomized controlled trials. Am J Clin Nutr.
39 Szajewska H, Horvath A, Koletzko B. (2006). Effect of n-3 long-chain polyunsaturated fatty acid supplementation of women with low-risk pregnancies on pregnancy outcomes and growth measures at birth: a meta-analysis of randomized controlled trials. Am J Clin Nutr.
40 Udell T, Gibson RA, Makrides M, et al. (2005). The effect of alpha-linolenic acid and linoleic acid on the growth and development of formula-fed infants: a systematic review and meta-analysis of randomized controlled trials. Lipids.
41 Wojcicki JM, Heyman MB. (2011). Maternal omega-3 fatty acid supplementation and risk for perinatal maternal depression. J Matern Fetal Neonatal Med.
42 Wright K, Coverston C, Tiedeman M, et al. (2006). Formula supplemented with docosahexaenoic acid (DHA) and arachidonic acid (ARA): a critical review of the research. Journal for Specialists in Pediatric Nursing: JSPN.
43 Yang H, Xun P, He K. (2013). Fish and fish oil intake in relation to risk of asthma: a systematic review and meta-analysis. PLoS ONE [Electronic Resource].
44 Zhang P, Lavoie PM, Lacaze-Masmonteil T, et al. (2014). Omega-3 long-chain polyunsaturated fatty acids for extremely preterm infants: a systematic review. Pediatrics.

## Observational studies with less than a sample size of 250 - N=33

1 Barman M, Johansson S, Hesselmar B, et al. (2013). High levels of both n-3 and n-6 long-chain polyunsaturated fatty acids in cord serum phospholipids predict allergy development. PLoS ONE [Electronic Resource].
2 Birberg-Thornberg U, Karlsson T, Gustafsson PA, et al. (2006). Nutrition and theory of mind--The role of polyunsaturated fatty acids (PUFA) in the development of theory of mind. Prostaglandins Leukotrienes & Essential Fatty Acids.
3 Birch EE, Khoury JC, Berseth CL, et al. (2010). The impact of early nutrition on incidence of allergic manifestations and common respiratory illnesses in children. J Pediatr.
4 Boucher O, Burden MJ, Muckle G, et al. (2011). Neurophysiologic and neurobehavioral evidence of beneficial effects of prenatal omega-3 fatty acid intake on memory function at school age. Am J Clin Nutr.
5 Browne JC, Scott KM, Silvers KM. (2006). Fish consumption in pregnancy and omega-3 status after birth are not associated with postnatal depression. J Affect Disord.
6 Cheruku SR, Montgomery-Downs HE, Farkas SL, et al. (2002). Higher maternal plasma docosahexaenoic acid during pregnancy is associated with more mature neonatal sleep-state patterning. Am J Clin Nutr.
7 Colombo J, Kannass KN, Shaddy DJ, et al. (2004). Maternal DHA and the development of attention in infancy and toddlerhood. Child Dev.
8 da Rocha CM, Kac G. (2012). High dietary ratio of omega-6 to omega-3 polyunsaturated acids during pregnancy and prevalence of post-partum depression. Matern Child Nutr.
9 De Vriese SR, Matthys C, De Henauw S, et al. (2002). Maternal and umbilical fatty acid status in relation to maternal diet. Prostaglandins Leukotrienes & Essential Fatty Acids.
10 Gale CR, Marriott LD, Martyn CN, et al. (2010). Breastfeeding, the use of docosahexaenoic acid-fortified formulas in infancy and neuropsychological function in childhood. Arch Dis Child.
11 Gustafsson PA, Duchen K, Birberg U, et al. (2004). Breastfeeding, very long polyunsaturated fatty acids (PUFA) and IQ at 6 1/2 years of age. Acta Paediatr.
12 Jacobson JL, Jacobson SW, Muckle G, et al. (2008). Beneficial effects of a polyunsaturated fatty acid on infant development: evidence from the inuit of arctic Quebec. J Pediatr.
13 Kannass KN, Colombo J, Carlson SE. (2009). Maternal DHA levels and toddler free-play attention. Dev Neuropsychol.
14 Lowe AJ, Thien FC, Stoney RM, et al. (2008). Associations between fatty acids in colostrum and breast milk and risk of allergic disease. Clin Exp Allergy.
15 Lundqvist-Persson C, Lau G, Nordin P, et al. (2010). Early behaviour and development in breast-fed premature infants are influenced by omega-6 and omega-3 fatty acid status. Early Hum Dev.
16 Magnusardottir AR, Steingrimsdottir L, Thorgeirsdottir H, et al. (2009). Red blood cell n-3 polyunsaturated fatty acids in first trimester of pregnancy are inversely associated with placental weight. Acta Obstet Gynecol Scand.
17 Markhus MW, Skotheim S, Graff IE, et al. (2013). Low omega-3 index in pregnancy is a possible biological risk factor for postpartum depression. PLoS ONE [Electronic Resource].
18 Montes R, Chisaguano AM, Castellote AI, et al. (2013). Fatty-acid composition of maternal and umbilical cord plasma and early childhood atopic eczema in a Spanish cohort. Eur J Clin Nutr.
19 Oddy WH, Pal S, Kusel MM, et al. (2006). Atopy, eczema and breast milk fatty acids in a high-risk cohort of children followed from birth to 5 yr. Pediatr Allergy Immunol.
20 Olsen SF, Hansen HS, Jensen B, et al. (1989). Pregnancy duration and the ratio of long-chain n-3 fatty acids to arachidonic acid in erythrocytes from Faroese women. J Intern Med.
21 Olsen SF, Hansen HS, Secher NJ, et al. (1995). Gestation length and birth weight in relation to intake of marine n-3 fatty acids. Br J Nutr.
22 Parra-Cabrera S, Moreno-Macias H, Mendez-Ramirez I, et al. (2008). Maternal dietary omega fatty acid intake and auditory brainstem-evoked potentials in Mexican infants born at term: cluster analysis. Early Hum Dev.
23 Pedersen L, Lauritzen L, Brasholt M, et al. (2012). Polyunsaturated fatty acid content of mother's milk is associated with childhood body composition. Pediatr Res.
24 Pittaluga E, Vernal P, Llanos A, et al. (2011). Benefits of supplemented preterm formulas on insulin sensitivity and body composition after discharge from the neonatal intensive care unit. J Pediatr.
25 Rees A, Sirois S, Wearden A. (2014). Maternal docosahexaenoic acid intake levels during pregnancy and infant performance on a novel object search task at 22 months. Child Development S2- Child Development: Abstracts & Bibliography.
26 Rzehak P, Koletzko S, Koletzko B, et al. (2011). Growth of infants fed formula rich in canola oil (low erucic acid rapeseed oil). Clin Nutr.
27 Soto-Ramirez N, Karmaus W, Zhang H, et al. (2012). Fatty acids in breast milk associated with asthma-like symptoms and atopy in infancy: a longitudinal study. J Asthma.
28 Stokes-Riner A, Thurston SW, Myers GJ, et al. (2011). A longitudinal analysis of prenatal exposure to methylmercury and fatty acids in the Seychelles. Neurotoxicol Teratol.
29 Stoney RM, Woods RK, Hosking CS, et al. (2004). Maternal breast milk long-chain n-3 fatty acids are associated with increased risk of atopy in breastfed infants. Clin Exp Allergy.
30 Strain JJ, Davidson PW, Bonham MP, et al. (2008). Associations of maternal long-chain polyunsaturated fatty acids, methyl mercury, and infant development in the Seychelles Child Development Nutrition Study. Neurotoxicology.
31 Tanaka K, Kon N, Ohkawa N, et al. (2009). Does breastfeeding in the neonatal period influence the cognitive function of very-low-birth-weight infants at 5 years of age?. Brain Dev.
32 Toro-Ramos T. (2013). The relationship between maternal body composition and diet with fetal development in low-income women in Brazil. Dissertation Abstracts International: Section B: The Sciences and Engineering.
33 Zornoza-Moreno M, Fuentes-Hernandez S, Carrion V, et al. (2014). Is low docosahexaenoic acid associated with disturbed rhythms and neurodevelopment in offsprings of diabetic mothers?. Eur J Clin Nutr.

## No numerical data - N=1

1 Lumia M, Luukkainen P, Kaila M, et al. (2012). Maternal dietary fat and fatty acid intake during lactation and the risk of asthma in the offspring. Acta Paediatrica.