# Appendix A Search Strategy

## DATABASE SEARCHED & TIME PERIOD COVERED

PsycINFO – 1/1/2000-8/24/2015

## LANGUAGE

English

## SEARCH STRATEGY

[ TI ( omega 3 or omega-3 or omega3 OR polyunsaturated or pufa or dha or epa or “long chain” or long-chain or longchain OR Docosapentanoic or docosapentaenoic or docosahexanoic or docosahexaenoic or dpa or dha OR eicosapentanoic or eicosapentaenoic or icosapent* ) OR SU ( omega 3 or omega-3 or omega3 OR polyunsaturated or pufa or dha or epa or “long chain” or long-chain or longchain OR Docosapentanoic or docosapentaenoic or docosahexanoic or docosahexaenoic or dpa or dha OR eicosapentanoic or eicosapentaenoic or icosapent* ) OR AB ( omega 3 or omega-3 or omega3 OR polyunsaturated or pufa or dha or epa or “long chain” or long-chain or longchain OR Docosapentanoic or docosapentaenoic or docosahexanoic or docosahexaenoic or dpa or dha OR eicosapentanoic or eicosapentaenoic or icosapent* )

OR

TI ( ((fatty acid or fatty acids*) and essential ) OR “fish oil” or “fish oils” or linolenic or alpha-linolenic OR alphalinolenic or alpha-linolenic OR linolenate or cervonic or timnodonic or stearidonic ) OR SU ( ((fatty acid or fatty acids*) and essential ) OR “fish oil” or “fish oils” or linolenic or alpha-linolenic OR alphalinolenic or alpha-linolenic OR linolenate or cervonic or timnodonic or stearidonic ) OR AB ( ((fatty acid or fatty acids*) and essential ) OR “fish oil” or “fish oils” or linolenic or alpha-linolenic OR alphalinolic or alpha-linolenic OR linolenate or cervonic or timnodonic or stearidonic )

OR

((n 3 or n3 or n-3) and (oil or oils or pufa or fatty acid or fatty acids)) OR ((menhaden or flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or perilla or shiso) and (oil or oils)) OR walnut* or butternut*or soybean* or “pumpkin seed” or pumpkinseed* OR “cod liver oil” or “codliver oil” or “marine oil” or “marine oils” or “marine fat” ) OR SU ( ((n 3 or n3 or n-3) and (oil or oils or pufa or fatty acid or fatty acids)) OR ((menhaden or flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or perilla or shiso) and (oil or oils)) OR walnut* or butternut*or soybean* or “pumpkin seed” or pumpkinseed* OR “cod liver oil” or “codliver oil” or “marine oil” or “marine oils” or “marine fat” ) OR AB ( ((n 3 or n3 or n-3) and (oil or oils or pufa or fatty acid or fatty acids)) OR ((menhaden or flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or perilla or shiso) and (oil or oils)) OR walnut* or butternut*or soybean* or “pumpkin seed” or pumpkinseed* OR “cod liver oil” or “codliver oil” or “marine oil” or “marine oils” or “marine fat” )

OR

TI ( salmon or mackerel or herring or tuna or halibut or seaweed or anchov* or sardine* OR Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega or Lovaza or Vascepa or icosapent ethyl OR ((fish n3 consum*) or (fish n3 intake) or (fish n3 diet*)) OR mediterranean n3 diet* ) OR SU ( salmon or mackerel or herring or tuna or halibut or seaweed or anchov* or sardine* OR Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega or Lovaza or Vascepa or icosapent ethyl OR ((fish n3 consum*) or (fish n3 intake) or (fish n3 diet*)) OR mediterranean n3 diet* ) OR AB ( salmon or mackerel or herring or tuna or halibut or seaweed or anchov* or sardine* OR Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega or Lovaza or Vascepa or icosapent ethyl OR ((fish n3 consum*) or (fish n3 intake) or (fish n3 diet*)) OR mediterranean n3 diet* ) ]

AND

[ TI ( growth OR ((child* n3 development) or gestational age or premature infant or low birth weight OR ( gestat* and (age* or durat* or week*)) OR prematur* or preterm or pre-term OR ( low n3 (birthweight or weight)) ) OR SU ( growth OR ((child* n3 development) or gestational age or premature infant or low birth weight OR ( gestat* and (age* or durat* or week*)) OR prematur* or preterm or pre-term OR ( low n3 (birthweight or weight)) ) OR SU ( growth OR ((child* n3 development) or gestational age or premature infant or low birth weight OR ( gestat* and (age* or durat* or week*)) OR prematur* or preterm or pre-term OR ( low n3 (birthweight or weight)) ) OR AB ( growth OR ((child* n3 development) or gestational age or premature infant or low birth weight OR ( gestat* and (age* or durat* or week*)) OR prematur* or preterm or pre-term OR ( low n3 (birthweight or weight)) )

OR

TI ( newborn or neonat* OR Retinopathy n3 Prematurity OR retrolental fibroplasia* OR ADHD or attention deficit disorder* OR atopic n3 dermatitis ) OR SU ( newborn or neonat* OR Retinopathy n3 Prematurity OR retrolental fibroplasia* OR ADHD or attention deficit disorder* OR atopic n3 dermatitis ) OR AB ( newborn or neonat* OR Retinopathy n3 Prematurity OR retrolental fibroplasia* OR ADHD or attention deficit disorder* OR atopic n3 dermatitis )

OR

TI ( autism OR autistic OR asperger* OR ados OR hypersensitiv* OR allerg* OR ( Fetal AND growth AND retard* ) OR ( Embryo* AND Fetal Development ) OR ( Fetus OR ((fetal OR fetus OR intrauterine) AND (growth OR develop*)) ) ) OR SU ( autism OR autistic OR asperger* OR ados OR hypersensitiv* OR allerg* OR ( Fetal AND growth AND retard* ) OR ( Embryo* AND Fetal Development ) OR ( Fetus OR ((fetal OR fetus OR intrauterine) AND (growth OR develop*)) ) ) OR AB (( autism OR autistic OR asperger* OR ados OR hypersensitiv* OR allerg* OR ( Fetal AND growth AND retard* ) OR ( Embryo* AND Fetal Development ) OR ( Fetus OR ((fetal OR fetus OR intrauterine) AND (growth OR develop*)) ) )

OR

TI ( Preeclamp* OR pre-eclamp* OR (Pregnan* AND Toxemi*) OR ( (Gestation* OR pregnan*) AND (hypertens* OR toxemi*) ) OR ( gestat* AND (child* OR newborn* OR infan* OR neonat* OR baby OR babies OR pediatr* OR paediatr*) ) OR ( depression AND (postpartum OR postnatal OR post-partum OR post-natal OR post partum OR post natal OR ante-natal OR antenatal OR ante natal) ) OR ( grow* near/3 (child* OR infant* OR infancy) ) ) OR SU (Preeclamp* OR pre-eclamp* OR (Pregnan* AND Toxemi*) OR ( (Gestation* OR pregnan*) AND (hypertens* OR toxemi*) ) OR ( gestat* AND (child* OR newborn* OR infan* OR neonat* OR baby OR babies OR pediatr* OR paediatr*) ) OR ( depression AND (postpartum OR postnatal OR post-partum OR post-natal OR post partum OR post natal OR ante-natal OR antenatal OR ante natal) ) OR ( grow* near/3 (child* OR infant* OR infancy) ) ) OR AB ( Preeclamp* OR pre-eclamp* OR (Pregnan* AND Toxemi*) OR ( (Gestation* OR pregnan*) AND (hypertens* OR toxemi*) ) OR ( gestat* AND (child* OR newborn* OR infan* OR neonat* OR baby OR babies OR pediatr* OR paediatr*) ) OR ( depression AND (postpartum OR postnatal OR post-partum OR post-natal OR post partum OR post natal OR ante-natal OR antenatal OR ante natal) ) OR ( grow* near/3 (child* OR infant* OR infancy) ) )

OR

TI ( ( congenital AND (vision near/3 disorder*) ) OR ( (learning near/3 disorder*) OR dyslexi* OR discalculi* ) OR ( (respiratory near/3 illness) OR asthma* OR wheez* OR respiratory syncitial virus ) ) OR SU ( ( congenital AND (vision near/3 disorder*) ) OR ( (learning near/3 disorder*) OR dyslexi* OR discalculi* ) OR ( (respiratory near/3 illness) OR asthma* OR wheez* OR respiratory syncitial virus ) ) OR AB ( ( congenital AND (vision near/3 disorder*) ) OR ( (learning near/3 disorder*) OR dyslexi* OR discalculi* ) OR ( (respiratory near/3 illness) OR asthma* OR wheez* OR respiratory syncitial virus ) ) ]

AND

Population Group: Human

Search modes - Find all search terms

=====================================================================================

## DATABASE SEARCHED & TIME PERIOD COVERED

Medline on OVID – 1/1/2000-8/25/2015

## LANGUAGE

English

## SEARCH STRATEGY

1. exp Growth/ or exp Gestational Age/ or Infant, Premature/ or Infant, Low Birth Weight/
2. limit 1 to (english language and yr=“2014 - 2015”)
3. (gestat* and (age* or durat* or week*)).mp.
4. limit 3 to (english language and yr=“2014 - 2015”)
5. (prematur* or preterm or pre-term).mp.
6. limit 5 to (english language and yr=“2014 - 2015”)
7. ((Infant* or baby) adj3 (low adj3 (birthweight or weight))).mp.
8. limit 7 to (english language and yr=“2014 - 2015”)
9. ((Infant$ or baby or birth) adj3 (prematur$ or gestational age)).mp.
10. limit 9 to (english language and yr=“2014 - 2015”)
11. (newborn or neonatal).mp.
12. limit 11 to (english language and yr=“2014 - 2015”)
13. Retinopathy of Prematurity/
14. limit 13 to (english language and yr=“2014 - 2015”)
15. retrolental fibroplasia$.mp.
16. limit 15 to (english language and yr=“2014 - 2015”)
17. Retinopathy of Prematurity.tw.
18. limit 17 to (english language and yr=“2014 - 2015”)
  527
19. Attention Deficit Disorder with Hyperactivity/ or ADHD.mp. or attention deficit disorder*.mp.
20. limit 19 to (english language and yr=“2014 - 2015”)
21. Dermatitis, Atopic/ or (atopic adj3 dermatitis).mp.
22. limit 21 to (english language and yr=“2014 - 2015”)
23. (autism or autistic).mp. or Autistic Disorder/ or asperger*.mp. or Asperger Syndrome/
24. limit 23 to (english language and yr=“2014 - 2015”)
25. ados.mp.
26. limit 25 to (english language and yr=“2014 - 2015”)
27. Hypersensitivity/ or allerg*.mp.
28. limit 27 to (english language and yr=“2014 - 2015”)
29. Fetal Growth Retardation/
30. limit 29 to (english language and yr=“2014 - 2015”)
31. exp Embryo/ and Fetal Development/
32. limit 31 to (english language and yr=“2014 - 2015”)
33. exp Fetus/
34. limit 33 to (english language and yr=“2014 - 2015”)
35. ((fetal or fetus or intrauterine) adj3 (growth or develop$)).mp.
36. limit 35 to (english language and yr=“2014 - 2015”)
37. Pre-Eclampsia/
38. limit 37 to (english language and yr=“2014 - 2015”)
39. (Preeclamp$ or pre-eclamp*).mp.
40. limit 39 to (english language and yr=“2014 - 2015”)
41. (Pregnan$ adj10 Toxemia$).mp.
42. limit 41 to (english language and yr=“2014 - 2015”)
43. ((gestation$ or pregnan$) and (hypertens$ or toxemia$)).mp.
44. limit 43 to (english language and yr=“2014 - 2015”)
45. (gestat$ and (child$ or newborn$ or infan$ or neonat$ or baby or babies or pediatr$ or paediatr$)).mp.
46. limit 45 to (english language and yr=“2014 - 2015”)
47. Depression, Postpartum/ or (depression adj3 (postpartum or postnatal or post-partum or post-natal or post partum or post natal or ante-natal or antenatal or ante natal)).mp.
48. limit 47 to (english language and yr=“2014 - 2015”)
49. (grow* adj3 (child* or infant* or infancy)).mp.
50. limit 49 to (english language and yr=“2014 - 2015”)
51. congenital.mp. and (Vision Disorders/ or (vision adj3 disorder*).mp.) {Including Related Terms}
52. limit 51 to (english language and yr=“2014 - 2015”)
53. Learning Disorders/ or (learning adj3 disorder*).mp. or dyslexi*.mp. or discalculi*.mp.
54. limit 53 to (english language and yr=“2014 - 2015”)
55. ((respiratory adj3 illness) or asthma* or wheez* or respiratory syncitial virus).mp.
56. limit 55 to (english language and yr=“2014 - 2015”)
57. 2 or 4 or 6 or 8 or 10 or 12 or 14 or 16 or 18 or 20 or 22 or 24 or 26 or 28 or 30 or 32 or 34 or 36 or 38 or 40 or 42 or 44 or 46 or 48 or 50 or 52 or 54 or 56
58. exp fatty acids, omega-3/
59. limit 58 to (english language and yr=“2014 - 2015”)
60. fatty acids, essential/ or linolenic acids/ or exp fish oils/
61. limit 60 to (english language and yr=“2014 - 2015”)
62. (omega 3 or omega-3 or omega3).mp.
63. limit 62 to (english language and yr=“2014 - 2015”)
64. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain).mp.
65. limit 64 to (english language and yr=“2014 - 2015”)
66. Docosapenta?noic.mp.
67. limit 66 to (english language and yr=“2014 - 2015”)
68. DPA.mp.
69. limit 68 to (english language and yr=“2014 - 2015”)
70. ((omega-3 or omega 3 or omega3) and fatty acid$).mp.
71. limit 70 to (english language and yr=“2014 - 2015”)
72. ((n 3 or n3 or n-3) and (oil$ or pufa or fatty acid$ or omega 3)).mp.
73. limit 72 to (english language and yr=“2014 - 2015”)
74. Docosahexaenoic Acids/
75. limit 74 to (english language and yr=“2014 - 2015”)
76. docosahexa?noic.mp.
77. limit 76 to (english language and yr=“2014 - 2015”)
78. Eicosapentaenoic Acid/
79. limit 78 to (english language and yr=“2014 - 2015”)
80. eicosapenta?noic.mp.
81. limit 80 to (english language and yr=“2014 - 2015”)
82. icosapent?enoic.mp.
83. limit 82 to (english language and yr=“2014 - 2015”)
84. (alpha linolenic or alphalinolenic or alpha-linolenic).mp.
85. limit 84 to (english language and yr=“2014 - 2015”)
86. (linolenate or cervonic or timnodonic or stearidonic).mp.
87. limit 86 to (english language and yr=“2014 - 2015”)
88. menhaden oil$.mp.
89. limit 88 to (english language and yr=“2014 - 2015”)
90. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or perilla or shiso) adj2 oil$).mp.
91. limit 90 to (english language and yr=“2014 - 2015”)
92. (walnut$ or butternut$ or soybean$ or pumpkin seed$).mp.
93. limit 92 to (english language and yr=“2014 - 2015”)
94. (fish adj2 oil$).mp.
95. limit 94 to (english language and yr=“2014 - 2015”)
96. (cod liver oil$ or codliver oil$ or marine oil$ or marine fat$).mp.
97. limit 96 to (english language and yr=“2014 - 2015”)
98. (salmon or mackerel or herring or tuna or halibut or seaweed or anchov$ or sardine$).mp.
99. limit 98 to (english language and yr=“2014 - 2015”)
100. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega or Lovaza or Vascepa or icosapent ethyl).mp.
101. limit 100 to (english language and yr=“2014 - 2015”)
102. (fish consumption or fish intake or (fish adj2 diet$)).mp.
103. limit 102 to (english language and yr=“2014 - 2015”)
104. (mediterranean adj diet$).mp.
105. limit 104 to (english language and yr=“2014 - 2015”)
106. ((red blood cell or phospholipid or plasma fatty acid or plasma or phospholipid or triacylglycerol or cholesteryl or ester or adipos$ or fatty acid or erythrocyte or ghost or platelet or granulocyte or neutrophil or mononuclear or LDL or HDL) and (DHA or docosahexa?noic or EPA or eicosapenta?noic or SDA or stearidonic or omega)).mp.
107. limit 106 to (english language and yr=“2014 - 2015”)
108. 59 or 61 or 63 or 65 or 67 or 69 or 71 or 73 or 75 or 77 or 79 or 81 or 83 or 85 or 87 or 89 or 91 or 93 or 95 or 97 or 99 or 101 or 103 or 105 or 107
109. 57 and 108
110. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
111. limit 110 to (english language and yr=“2014 - 2015”)
112. (exp clinical trial/ or evaluation studies or follow-up studies or prospective studies or exp randomized controlled trials/ or exp Randomized Controlled Trials as Topic/) {Including Related Terms}
113. limit 112 to (english language and yr=“2014 - 2015”)
114. exp random allocation/ or exp double-blind method/ or exp single-blind method/
115. limit 114 to (english language and yr=“2014 - 2015”)
116. exp placebos/ or exp longitudinal studies/ or exp cohort studies/
117. limit 116 to (english language and yr=“2014 - 2015”)
118. (“prospective studies” or “prospective study”).af.
119. limit 118 to (english language and yr=“2014 - 2015”)
120. Cross-Sectional Studies.sh.
121. limit 120 to (english language and yr=“2014 - 2015”)
122. (clin$ adj trial$).af.
123. limit 122 to (english language and yr=“2014 - 2015”)
124. ((evaluation adj3 study) or (evaluation adj3 studies)).af.
125. limit 124 to (english language and yr=“2014 - 2015”)
126. (followup or follow-up or (follow$ adj2 up)).af. NOTE: SEARCH ENGINE DID NOT ACCEPT THIS AS A PHRASE
127. limit 126 to (english language and yr=“2014 - 2015”)
128. (follow-up or “follow up”).af. NOTE: SEARCH ENGINE DID NOT ACCEPT THIS AS A PHRASE
129. limit 128 to (english language and yr=“2014 - 2015”)
130. (“following up” or “followed up”).af. NOTE: SEARCH ENGINE DID NOT ACCEPT THIS AS A PHRASE
131. limit 130 to (english language and yr=“2014 - 2015”)
132. ((prospective adj3 study) or (prospective adj3 studies)).af.
133. limit 132 to (english language and yr=“2014 - 2015”)
134. (prospective adj3 observational).af.
135. limit 134 to (english language and yr=“2014 - 2015”)
136. (multicenter or multi-center).af.
137. limit 136 to (english language and yr=“2014 - 2015”)
138. (random$ or rct$).af.
139. limit 138 to (english language and yr=“2014 - 2015”)
140. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).af.
141. limit 140 to (english language and yr=“2014 - 2015”)
142. (placebo$ or comparative study or longitudinal or cohort* or observational or cross section$ or cross-section$ or food frequency questionnaire$).af.
143. limit 142 to (english language and yr=“2014 - 2015”)
144. “before-and-after”.af. NOTE: SEARCH ENGINE DID NOT ACCEPT THIS AS A PHRASE
145. limit 144 to (english language and yr=“2014 - 2015”)
146. ((before adj2 after) or single-arm or “single arm”).af.
147. limit 146 to (english language and yr=“2014 - 2015”)
148. (single-arm or “single arm”).af.
149. limit 148 to (english language and yr=“2014 - 2015”)
150. “before-and-after”.af. NOTE: SEARCH ENGINE DID NOT ACCEPT THIS AS A PHRASE
151. limit 150 to (english language and yr=“2014 - 2015”)
152. 111 or 113 or 115 or 117 or 119 or 121 or 123 or 125 or 127 or 129 or 131 or 133 or 135 or 137 or 139 or 141 or 143 or 145 or 147 or 149 or 151
153. 109 and 152

=====================================================================================

## DATABASE SEARCHED & TIME PERIOD COVERED

Embase – 1/1/2000-8/25/2015

## LANGUAGE

English

## SEARCH STRATEGY

#1 ‘body growth’/exp OR ‘body growth’ OR ‘child development’/exp OR ‘child development’ OR ‘gestational age’/exp OR ‘gestational age’ OR ‘prematurity’/exp OR ‘prematurity’ OR ‘low birth weight’/exp OR ‘low birth weight’
#2 gestat* AND (age* OR durat* OR week*)
#3 premature* OR preterm OR ‘pre term’
#4 infant* OR ‘baby’/exp OR baby AND low AND (‘birthweight’/exp OR birthweight OR ‘weight’/exp OR weight)
#5 ‘newborn’/exp OR newborn OR neonat*
#6 ‘retrolental fibroplasia’/exp OR ‘retrolental fibroplasia’ OR ‘attention deficit disorder’/exp OR ‘attention deficit disorder’ OR ‘atopic dermatitis’/exp OR ‘atopic dermatitis’ OR ‘autism’/exp OR ‘autism’ OR ‘hypersensitivity’/exp OR ‘hypersensitivity’
#7 retrolental AND fibroplas* OR retinopathy NEAR/2 prematurity OR (‘attention’/exp OR attention AND deficit AND (‘disorder’/exp OR disorder)) OR ‘adhd’/exp OR adhd OR atopic NEAR/3 dermatitis OR ‘autism’/exp OR autism OR autistic OR asperger* OR ados OR allerg*
#8 retrolental AND fibroplas* OR retinopathy NEAR/2 prematurity OR (‘attention’ OR ‘attention’/exp OR attention AND deficit AND (‘disorder’ OR ‘disorder’/exp OR disorder)) OR ‘adhd’ OR ‘adhd’/exp OR adhd OR atopic NEAR/3 dermatitis OR ‘autism’ OR ‘autism’/exp OR autism OR autistic OR asperger* OR ados OR allerg*
#9 ‘intrauterine growth retardation’/exp OR ‘intrauterine growth retardation’ OR ‘prenatal development’/exp OR ‘prenatal development’ OR ‘fetus’/exp OR ‘fetus’ OR ‘preeclampsia’/exp OR ‘preeclampsia’ OR ‘puerperal depression’/exp OR ‘puerperal depression’
#10 (fetal OR fetus OR intrauterine) NEAR/3 (growth OR develop*)
#11 preeclamp* OR ‘pre eclampsia’/exp OR ‘pre eclampsia’
#12 pregnan* NEAR/10 toxemi*
#13 gestation* OR pregnan* AND (hypertens* OR toxemi*)
#14 gestation* AND (child* OR newborn* OR infan* OR neonat* OR ‘baby’/exp OR baby OR babies OR pediatr* OR paediatr*)
#15 depression NEAR/3 (postpartum OR postnatal OR ‘post partum’ OR ‘post natal’ OR antenatal OR ‘ante natal’)
#16 grow* NEAR/3 (child* OR infant* OR infancy)
#17 ‘visual disorder’/exp OR ‘visual disorder’ AND congenital
#18 congenital AND (‘vision’/exp OR vision OR visual) AND disorder*
#19 ‘learning disorder’/exp OR ‘learning disorder’ OR learning NEAR/3 disorder* OR dyslexi* OR discalculi*
#20 respiratory NEAR/3 illness OR respiratory NEAR/3 disease* OR respiratory NEAR/3 condition* OR asthma* OR wheez* OR (respiratory AND syncytial AND (‘virus’/exp OR virus))
#21 infant* OR ‘baby’/exp OR baby AND (premature* OR gestational) AND (‘age’/exp OR age)
#22 #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21
#23 #3 AND (2014:py OR 2015:py)
#24 #3 AND (2014:py OR 2015:py) AND [english]/lim
#25 ‘icosapentaenoic acid’/exp OR ‘icosapentaenoic acid’
#26 ‘docosahexaenoic acid’/exp OR ‘docosahexaenoic acid’
#27 ‘omega 3 fatty acid’/exp OR ‘omega 3 fatty acid’
#28 ‘essential fatty acid’/exp OR ‘essential fatty acid’
#29 ‘fish oil’/exp OR ‘fish oil’
#30 ‘omega 3’/exp OR ‘omega 3’ OR (‘omega’/exp OR omega AND 3) OR omega3 OR (polyunsaturated AND fat*) OR pufa OR dha OR epa OR dpa OR (long AND chain) OR ‘long chain’
#31 ‘docosapentaenoic acid’/exp OR ‘docosapentaenoic acid’ OR docosapent* OR docosahex* OR eicosapent* OR icosapent*
#32 n3 OR ‘n 3’ OR (n AND 3) AND (oil* OR pufa OR fatty) AND acid*
#33 alpha AND linolenic OR alphalinolenic OR ‘alpha linolenic’
#34 linolenate* OR cervonic OR timnodonic OR stearidonic
#35 menhaden NEAR/3 oil*
#36 flax* OR ‘linseed’ OR ‘linseed’/exp OR linseed OR (‘rape’ OR ‘rape’/exp OR rape AND (‘seed’ OR ‘seed’/exp OR seed)) OR ‘rapeseed’ OR ‘rapeseed’/exp OR rapeseed
#37 ‘canola’ OR ‘canola’/exp OR canola OR soy OR soybean* OR ‘walnut’ OR ‘walnut’/exp OR walnut
#38 ‘mustard’ OR ‘mustard’/exp OR mustard AND (‘seed’ OR ‘seed’/exp OR seed)
#39 ‘perilla’ OR ‘perilla’/exp OR perilla OR shiso
#40 walnut* OR butternut* OR soybean* OR (‘pumpkin’ OR ‘pumpkin’/exp OR pumpkin AND (‘seed’ OR ‘seed’/exp OR seed)) OR pumpkinseed*
#41 fish NEAR/2 oil*
#42 cod AND (‘liver’ OR ‘liver’/exp OR liver) AND oil* OR (codliver AND oil*) OR (marine AND oil*) OR (marine AND (‘fat’/exp OR fat))
#43 ‘salmon’ OR ‘salmon’/exp OR salmon OR mackerel OR ‘herring’ OR ‘herring’/exp OR herring OR ‘tuna’ OR ‘tuna’/exp OR tuna OR ‘halibut’ OR ‘halibut’/exp OR halibut OR ‘seaweed’ OR ‘seaweed’/exp OR seaweed OR anchov* OR sardine*
#44 ropufa OR ‘maxepa’ OR ‘maxepa’/exp OR maxepa OR ‘omacor’ OR ‘omacor’/exp OR omacor OR ‘efamed’ OR ‘efamed’/exp OR efamed OR resq OR epagis OR almarin OR coromega OR ‘lovaza’ OR ‘lovaza’/exp OR lovaza OR ‘vascepa’ OR ‘vascepa’/exp OR vascepa OR (‘icosapent’ OR ‘icosapent’/exp OR icosapent AND ethyl)
#45 fish NEAR/2 consum* OR fish NEAR/2 intake OR fish NEAR/2 diet
#46 ‘mediterranean diet’/exp OR ‘mediterranean diet’
#47 red AND (‘blood’ OR ‘blood’/exp OR blood) AND (‘cell’ OR ‘cell’/exp OR cell) OR (‘plasma’ OR ‘plasma’/exp OR plasma AND fatty AND (‘acid’ OR ‘acid’/exp OR acid)) OR ‘plasma’ OR ‘plasma’/exp OR plasma OR ‘phospholipid’ OR ‘phospholipid’/exp OR phospholipid OR ‘triacylglycerol’ OR ‘triacylglycerol’/exp OR triacylglycerol OR cholesteryl OR ‘ester’ OR ‘ester’/exp OR ester OR adipos* OR (fatty AND (‘acid’ OR ‘acid’/exp OR acid)) OR ‘erythrocyte’ OR ‘erythrocyte’/exp OR erythrocyte OR ghost OR ‘platelet’ OR ‘platelet’/exp OR platelet OR ‘granulocyte’ OR ‘granulocyte’/exp OR granulocyte OR ‘neutrophil’ OR ‘neutrophil’/exp OR neutrophil OR mononuclear OR ‘ldl’ OR ‘ldl’/exp OR ldl OR ‘hdl’ OR ‘hdl’/exp OR hdl AND (dha OR docosahexa?noic OR epa OR eicosapenta?noic OR sda OR stearidonic OR ‘omega’ OR ‘omega’/exp OR omega)
#48 #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47
#49 #22 AND #48
#50 #34 AND (2014:py OR 2015:py)
#51 #34 AND (2014:py OR 2015:py) AND [english]/lim
#52 #34 AND (2014:py OR 2015:py) AND [humans]/lim

NUMBER OF RESULTS: 56

================================================================================

## DATABASE SEARCHED & TIME PERIOD COVERED

Cochrane Databases – 1/1/2000-8/26/2015

## LANGUAGE

English

## SEARCH STRATEGY

#1 MeSH descriptor: [Fatty Acids, Omega-3] explode all trees
#2 MeSH descriptor: [Fatty Acids, Essential] explode all trees
#3 MeSH descriptor: [Linolenic Acids] explode all trees
#4 MeSH descriptor: [Fish Oils] explode all trees
#5 MeSH descriptor: [Docosahexaenoic Acids] explode all trees
#6 MeSH descriptor: [Eicosapentaenoic Acid] explode all trees
#7 omega 3 or omega-3 or omega3:ti,ab,kw (Word variations have been searched)
#8 polyunsaturated or pufa or dha or epa or “long chain” or long-chain or longchain:ti,ab,kw (Word variations have been searched)
#9 Docosapentanoic or docosapentaenoic or docosahexanoic or docosahexaenoic or dpa or dha:ti,ab,kw (Word variations have been searched)
#10 icosapentanoic or eicosapentaenoic or icosapent*:ti,ab,kw (Word variations have been searched)
#11 (fatty acid or fatty acids*) and essential:ti,ab,kw (Word variations have been searched)
#12 “fish oil” or “fish oils” or linolenic or alpha-linolenic:ti,ab,kw (Word variations have been searched)
#13 alphalinolenic or alpha-linolenic:ti,ab,kw (Word variations have been searched)
#14 linolenate or cervonic or timnodonic or stearidonic:ti,ab,kw (Word variations have been searched)
#15 (n 3 or n3 or n-3) and (oil or oils or pufa or fatty acid or fatty acids):ti,ab,kw (Word variations have been searched)
#16 menhaden or flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy:ti,ab,kw (Word variations have been searched)
#17 soybean or walnut or mustard seed or perilla or shiso:ti,ab,kw (Word variations have been searched)
#18 walnut* or butternut* or soybean* or “pumpkin seed” or pumpkinseed*:ti,ab,kw (Word variations have been searched)
#19 “cod liver oil” or “codliver oil” or “marine oil” or “marine oils” or “marine fat”:ti,ab,kw (Word variations have been searched)
#20 salmon or mackerel or herring or tuna or halibut or seaweed or anchov* or sardine*:ti,ab,kw (Word variations have been searched)
#21 Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega or Lovaza:ti,ab,kw (Word variations have been searched)
#22 Vascepa or icosapent ethyl:ti,ab,kw (Word variations have been searched)
#23 (fish near/3 consum*) or (fish near/3 intake) or (fish near/3 diet*):ti,ab,kw (Word variations have been searched)
#24 mediterranean near/3 diet*:ti,ab,kw (Word variations have been searched)
#25 red blood cell or phospholipid or plasma fatty acid or plasma or phospholipid or triacylglycerol:ti,ab,kw (Word variations have been searched)
#26 cholesteryl or ester or adipos* or fatty acid or erythrocyte or ghost or platelet or granulocyte:ti,ab,kw (Word variations have been searched)
#27 neutrophil or mononuclear or LDL or HDL:ti,ab,kw (Word variations have been searched)
#28 EPA or SDA or stearidonic or omega:ti,ab,kw (Word variations have been searched)
#29 #25 or #26 or #27
#30 #29 and #28
#34 MeSH descriptor: [Growth] explode all trees
#35 MeSH descriptor: [Child Development] explode all trees
#36 MeSH descriptor: [Gestational Age] explode all trees
#37 MeSH descriptor: [Infant, Premature] explode all trees
#38 MeSH descriptor: [Infant, Premature] explode all trees
#39 MeSH descriptor: [Infant, Low Birth Weight] explode all trees
#40 MeSH descriptor: [Retinopathy of Prematurity] explode all trees
#41 MeSH descriptor: [Attention Deficit Disorder with Hyperactivity] explode all trees
#42 MeSH descriptor: [Dermatitis, Atopic] explode all trees
#43 MeSH descriptor: [Autistic Disorder] explode all trees
#44 MeSH descriptor: [Hypersensitivity] explode all trees
#45 MeSH descriptor: [Fetal Growth Retardation] explode all trees
#46 MeSH descriptor: [Embryonic and Fetal Development] explode all trees
#47 MeSH descriptor: [Fetus] explode all trees
#48 MeSH descriptor: [Pre-Eclampsia] explode all trees
#49 MeSH descriptor: [Depression, Postpartum] explode all trees
#50 MeSH descriptor: [Vision Disorders] explode all trees
#51 growth or (child* next/3 development) or gestational age or premature infant or low birth weight:ti,ab,kw (Word variations have been searched)
#52 gestat* and (age* or durat* or week*):ti,ab,kw (Word variations have been searched)
#53 prematur* or preterm or pre-term:ti,ab,kw (Word variations have been searched)
#54 low near/3 (birthweight or weight):ti,ab,kw (Word variations have been searched)
#55 newborn or neonat*:ti,ab,kw (Word variations have been searched)
#56 Retinopathy near/3 Prematurity:ti,ab,kw (Word variations have been searched)
#57 retrolental fibroplasia*:ti,ab,kw (Word variations have been searched)
#58 ADHD or attention deficit disorder*:ti,ab,kw (Word variations have been searched)
#59 atopic near/3 dermatitis:ti,ab,kw (Word variations have been searched)
#60 autism or autistic or asperger*:ti,ab,kw (Word variations have been searched)
#61 ados or hypersensitiv* or allerg*:ti,ab,kw (Word variations have been searched)
#62 Fetal and growth and retard*:ti,ab,kw (Word variations have been searched)
#63 Embryo* and Fetal Development:ti,ab,kw (Word variations have been searched)
#64 Fetus or ((fetal or fetus or intrauterine) and (growth or develop*)):ti,ab,kw (Word variations have been searched)
#65 (Preeclamp* or pre-eclamp*) or (Pregnan* and Toxemi*):ti,ab,kw (Word variations have been searched)
#66 (Gestation* or pregnan*) and (hypertens* or toxemi*):ti,ab,kw (Word variations have been searched)
#67 gestat* and (child*or newborn* or infan* or neonat*or baby or babies or pediatr* or paediatr*):ti,ab,kw (Word variations have been searched)
#68 depression and (postpartum or postnatal or post-partum or post-natal or post partum or post natal or ante-natal or antenatal or ante natal):ti,ab,kw (Word variations have been searched)
#69 grow* near/3 (child* or infant* or infancy):ti,ab,kw (Word variations have been searched)
#70 congenital and (vision near/3 disorder*):ti,ab,kw (Word variations have been searched)
#71 (learning near/3 disorder*) or dyslexi* or discalculi*:ti,ab,kw (Word variations have been searched)
#72 (respiratory near/3 illness) or asthma* or wheez* or respiratory syncitial virus:ti,ab,kw (Word variations have been searched)
#73 #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50
#74 #51 or #52 or #53 or #54 or #55 or #56 or #57 or #58 or #59 or #60 or #61 or #62 or #63 or #64 or #65 or #66 or #67 or #68 or #69 or #70 or #71 or #72
#75 #73 or #74
#76 #33 and #75

LIMITED TO 2014-2015

===========================================================================

## PUBMED “SIMILAR ARTICLE” SEARCH ON BABIN 2000

Babin F, Rodriguez A, Sarda P, Vandeputte B, Mendy F, Descomps B, et al. (2000). Alpha linolenic acid in cholesterol esters: a marker of alphalinolenic acid intake in newborns. Eur J Clin Nutr.

===========================================================================

## WEB OF SCIENCE FORWARD SEARCH ON BABIN 2000

===========================================================================

## SCOPUS FORWARD SEARCH ON BABIN 2000

===========================================================================

## DATABASE SEARCHED & TIME PERIOD COVERED

CAB ABSTRACTS – 1/1/2000-8/28/2015

## LANGUAGE

English

## SEARCH STRATEGY

ti(omega-3 OR omega3 OR “omega 3” OR “essential fatty acid” OR “essential fatty acids” OR linolenic OR “fish oil” OR “fish oils” OR polyunsaturated OR pufa OR dha OR epa OR long chain OR longchain OR Docosapentanoic OR Docosapentaenoic OR Docosahexaenoic OR Eicosapentaenoic OR icosapentaenoic OR ((n 3 OR n3 OR n-3) AND (oil OR pufa OR fatty acid OR omega 3)) OR alpha linolenic OR alphalinolenic OR alpha-linolenic OR linolenate OR cervonic OR timnodonic OR stearidonic OR butternut OR soybean OR pumpkin seed OR menhaden OR flax OR flaxseed OR flax seed OR linseed OR rape seed OR rapeseed OR canola OR soy OR soybean OR walnut OR mustard seed OR perilla OR shiso OR walnut OR “cod liver oil” OR “codliver oil” OR “marine oil” OR “marine oils” OR “marine fat” OR salmon OR mackerel OR herring OR tuna OR halibut OR seaweed OR anchov* OR sardine* OR Ropufa OR MaxEPA OR Omacor OR Efamed OR ResQ OR Epagis OR Almarin OR Coromega OR Lovaza OR Vascepa OR icosapent ethyl OR (fish AND (consum* OR intake OR diet*) ) OR “mediterranean diet” OR ((“Red blood cell” OR “red blood cells” OR phospholipid* OR plasma OR triacylglycerol OR cholesteryl OR ester OR adipos* OR fatty acid OR fatty acids OR erythrocyte OR ghost OR platelet* OR granulocyte OR neutrophil OR mononuclear OR LDL OR HDL) AND (EPA OR SDA OR stearidonic OR omega*)))

AND

ti((“Child Development” OR (gestat* AND (age* OR durat* OR week*)) OR prematur* OR preterm OR pre-term OR ((Infant* OR baby) AND (birthweight OR birth-weight OR weight)) OR newborn OR neonatal OR (grow* AND (child* OR infant* OR infancy)) OR “Retinopathy of Prematurity” OR “retrolental fibroplasia” OR ADHD OR attention deficit disorder* OR “atopic dermatitis” OR (congenital AND (“vision disorder”)) OR “learning disorder” OR “learning disorders” OR dyslexi* OR discalculi* OR “respiratory illness” OR asthma* OR wheez* OR respiratory syncitial virus OR autism OR autistic OR Asperger* OR ados OR hypersensitiv* OR allerg* OR (Fetal AND growth AND retard*) OR ((embryo* OR Fetus OR fetal OR fetus OR intrauterine) AND (growth OR develop*)) OR Preeclamp* OR pre-eclamp* OR ((Gestation* OR pregnan*) AND (hypertens* OR toxemi*)) OR (gestat* AND (child*or newborn* OR infan* OR neonat*or baby OR babies OR pediatr* OR paediatr*)) OR (depression AND (postpartum OR postnatal OR post-partum OR post-natal OR post partum OR post natal OR ante-natal OR antenatal OR ante natal)) OR (grow* AND (child* OR infant* OR infancy))))