# Abbreviations/Acronyms

Abbreviation: Meaning
ALA: A-linolenic acid
AA: Arachidonic Acid
AE: Adverse event
AHRQ: Agency for Healthcare Research and Quality
ASD: Autism Spectrum Disorder
BDI: Beck Depression Inventory
BMI: Body mass index
CI: Confidence Interval
DHA: Docosahexaenoic acid
DPA: Docosapentaenoic acid
EAR: Estimated Average Requirement
EEG: Electroencephalogram
EFA: Essential fatty acid
EPA: Eicosapentaenoic acid
EPC: Evidence-based Practice Center
EPDS: Edinburgh Pregnancy Depression Scale
FOS: Fructooligosaccharide
GHTN: Gestational hypertension
Hg: Mercury
HR: Hazard ratio
IUGR: Intrauterine growth retardation
KQ: Key Question
LBW: Low birth weight
LCPUFA: Long-chain polyunsaturated fatty acid
MA: Meta-analysis
MDI: Mental Development Index
Mg: Milligram
n-3 FA: Omega-3 fatty acid(s)
n-6 FA: Omega-6 fatty acid(s)
NOS: Newcastle-Ottawa Scale or Neurological Optimality Score
NR: Not reported
ODS: Office of Dietary Supplements
OR: Odds ratio
PDI: Psychomotor Development Index
PE: Preeclampsia or eclampsia
PPD: Post- or peripartum depression
PUFA: Polyunsaturated fatty acid
RBC: Red blood cell
RCT: Randomized controlled trial
RoB: Risk of bias
RR: Risk ratio
SD: Standard deviation
SDA: Stearidonic acid
SGA: Small for gestational age
SBP: Systolic blood pressure
SR: Systematic review
TEP: Technical Expert Panel
UK: United Kingdom