# Results

The Results chapter is organized as follows. The chapter starts with an overall description of the included studies and their risk of bias assessment. The bulk of the chapter is organized by outcome, with a description first of the randomized controlled trials (RCT) and their subgroup analyses, followed by the observational studies and their subgroup analyses. Within each description of studies, we follow the basic pattern of first describing the evidence regarding total omega-3 fatty acids (n-3 FA) combined, then alphalinolenic acid (ALA), the individual long-chain n-3 FA (eicosapentaenoic acid [EPA], docosahexaenoic acid [DHA], docosapentaenoic acid [DPA], and stearidonic acid [SDA]), and then combined long-chain n-3 FA (EPA+DHA±DPA). Within the description of the observational studies, we first present the results of associations with n-3 FA intake followed by n-3 FA biomarkers.

Appendix A presents the literature search strategies. Appendix B lists the articles that were reviewed in full text that were excluded, with their rejection reasons. Appendix C presents the study-level risk of bias assessments of all studies. Appendix D presents study-level baseline data. Appendix E presents study-level design features. Appendix F presents the study-level results data for the observational studies. Appendix G presents the “causality tables” described in the Methods section.

## Summary of Studies

The literature searches yielded 11,440 citations (Figure 3). Reference lists from existing systematic reviews yielded 203 additional citations (which mostly represented articles published before 2002). Of these, 829 abstracts met basic eligibility criteria. As described in the Methods chapter (under Study selection), using an evidence map process, we selected 463 articles for full text review, of which 147 articles met eligibility criteria, representing 61 RCTs (in 82 articles) and 37 longitudinal observational studies (in 65 articles).46–192

Figure 3 Literature flow

Abbreviations: CVD = cardiovascular disease, n-3 = omega-3 fatty acids, RCT = randomized controlled trial.

This figure demonstrates the process by which 61 randomized control trials (in 82 articles) and 37 observational studies (in 65 articles) were eligible for this review. From electronic database searches, there were 11,440 citations. An additional 203 studies were found in existing systematic reviews. From all of these combined, 10,414 were excluded based on abstract screening. An additional 366 studies were excluded after reviewing the evidence map. 463 full text studies were screened and an additional 316 were excluded for the following reasons: there was no outcome or analysis of interest, there was duplicate data, or case control study, or not a primary study, or a non-comparative study, or not peer reviewed, or the number of omega-3 dose data or not specifically omega-3, the study was a weight loss intervention, not longitudinal, of a duration of less than 4 weeks, not in English, the population considered was not general or subject to cardiovascular disease, or the study was not available.

## Study Risk of Bias

Across RCTs, the studies generally had few risk of bias concerns (Figure 4, Appendix C). Among the 61 RCTs, 23 (38%) had no high risk of bias/study quality limitations; an additional 26 RCTs (43%) had one risk of bias limitation and 6 (10%) had two risk of bias limitations. None of the remaining 6 RCTs (10%) had more than four study limitations (of 10 explicitly assessed potential limitations). The most common risk of bias limitation was a lack of intention-to-treat analyses; 12 RCTs (20%) clearly did not conduct intention-to-treat analyses (one of these conducted an intention-to-treat analysis for the outcome death, but not for lipid outcomes); 12 additional RCTs (20%) were unclear whether intention-to-treat analyses were conducted. Ten RCTs (16%) did not blind study participants (and 4 additional, 7%, were unclear whether they blinded participants), often because the intervention was dietary and could not be blinded. However, only 7 RCTs (11%) clearly did not blind outcome assessors (nine additional RCTs, 14%, were unclear regarding outcome assessor blinding). Attrition bias, primarily due to dropout rates greater than 20 percent, was present in 9 RCTs (15%). Other potential biases were less common.

Figure 4 Risk of bias of randomized controlled trials

Risk of bias, by specific question, of the 61 included randomized controlled trials. See Appendix C for details.

This figure demonstrates that, across randomized control trials. The studies generally had few risk of bias concerns. Considering the following categories: allocation concealment, outcome assessor blinding, outcome reporting bias, baseline similar or general, and compliance, at a minimum, between 50 and 60% of all randomized control trials had low risk of bias or study quality limitation, meaning none or one concern. Uncertainty of risk of bias existed in a small percentage of studies and smaller still, those with a high risk of bias were identified. Outcome reporting represents the highest risk of bias in the randomized control trials.

Across the observational studies, there were fairly few risk of bias concerns (Figure 5). Nine of 37 studies (24%) had no high risk of bias concerns; 20 (54%) had only a single high risk of bias concern (of 7 explicitly assessed potential limitations) and 6 (16%) had two risk of bias concerns. The 2 remaining studies (5%) had three risk of bias concerns. No study was deemed to have high risk of selection bias (regarding whether the outcome was present at baseline) and all adequately adjusted for confounders. The majority of studies used a dietary assessment tool that did not include dietary supplements (18 of 29 applicable studies; 62%); an additional 4 studies (14%) were unclear whether dietary supplements were used. Sixteen studies (43%) did not adequately reported baseline nutrient exposures. Bias due to lack of outcome assessor blinding was infrequent (3 studies [8%]; 4 studies [11%] were unclear), as was attrition bias (1 study [3%]; 4 studies [11%] were unclear). All observational studies reported multivariate analyses (this was an eligibility criterion).

Figure 5 Risk of bias of longitudinal, prospective observational studies

Risk of bias, by specific question, of the 37 included longitudinal observational studies. For dietary assessment, studies rated high risk of bias if only diet (not supplements) were included in the food frequency questionnaire; studies that evaluate only biomarkers were not evaluated for risk of bias for dietary assessment (not applicable). See Appendix C for details.

Abbreviations: n-3 FA = omega-3 fatty acids.

This figure demonstrates via a bar graph the relatively low risk of bias concerns across observational studies. The following categories are risk of bias concerns are represented on the y- axis: selection bias, complete adjustment, outcome assessor blinding, attrition bias, dietary assessment, omega-3 fatty acid exposure reporting. The x-axis shows percentages of studies that have low or good risk of bias, unclear or incomplete risk of bias, high or poor risk of bias, or not applicable based. The graph demonstrates that no study was deemed to have high risk of selection bias (regarding whether the outcome was present at baseline), but for three of 33 studies it was unclear. The most frequent reporting inadequacy related to whether the ranges and distribution of omega-3 fatty acid exposures were fully reported and among the studies included, there exists inadequate reporting of the dietary assessment instrument.

Tables 1 and 2 enumerate studies by n-3 FA, strength of evidence, and overall effect or association by outcome (clinical and intermediate separately). The table highlights the lack of sufficient evidence for most clinical cardiovascular disease (CVD) outcomes (empty cells and unshaded cells with black font). Only for marine oil (EPA+DHA) is there sufficient evidence for beneficial effect (or association) of higher n-3 FA intake. The body of evidence provides no sufficient evidence of a significant effect (or association) of ALA on CVD outcomes or examined risk factors.

Table 1 Enumeration of studies by clinical outcome and n-3 FA

Outcome | Total n-3 FA | | | Marine Oil | | | EPA | | | DHA | | | DPA | | | SDA | | | ALA | | | MvA
| R | OI | OB | R | OI | OB | R | OI | OB | R | OI | OB | R | OI | OB | R | OI | OB | R | OI | OB | R
Total (including intermediate outcomes) | 2 | 8 | 3 | 55 | 21 | 8 | 1 | 8 | 9 | 1 | 8 | 10 | | 2 | 6 | 2 | | 1 | 6 | 12 | 7 | 3
ACS | | 1 | | | 1 | 1 | | 1 | 1 | | 1 | 1 | | | 1
Angina | | | | L:6 | | | 1 | | | | | | | | | | | | 1
AFib | | | 1 | M:3 | 3 | | | | L:3 | | | 1 | | | L:3 | | | | | L:3 | 3
Card Death | | | | 5 | 1 | 1 | | | 1 | | | 1 | | | 1 | | | 1 | | | 1
CVD Death | | 4 | 1 | L:7 | 6 | | | 2 | 1 | | 2 | 1 | | | 1 | | | | 1 | 3 | 2
CHF | | | 1 | L:6 | 5 | 2 | | | 3 | | | 3 | | | 1 | | | | L:1 | 4 | 3
CHF Death | | 1 | | 1
CHD | | | 2 | | 7 | 1 | | L:2 | 3 | | L:2 | 3 | | | 3 | | | | | L:6
CHD Death | | 2 | 1 | L:4 | 7 | | 1 | 2 | 1 | | 2 | 1 | | | 1 | | | | L:1 | 4 | 1
Death, All-Cause | | 1 | 1 | H:17 | 3 | | 1 | | 3 | | | 3 | | | 1 | | | | 1 | | 2
HTN | | 2 | | | 1
MACE | | 3 | | H:10 | 3 | 2 | 1 | 1 | 3 | | 1 | 4 | | | 3 | | | 1 | 1 | 2
MI | | L:3 | | L:11 | 1 | | 1 | | 1 | | 1 | | | | | | | | 1
MI Death | | 2 | | | 1
Revasc | | | | H:6 | 1 | | 1
CVA Dth, Hem | | | | | 1 | | | 1 | | | 1
CVA Dth, Isch | | 2 | | | 1 | | | 1 | | | 1
CVA Dth, Tot | | L:4 | 1 | 2 | 1 | | 1 | 1 | 1 | | 1 | 1 | | | 1
CVA, Hem | | | 1 | L:2 | 5 | 1 | 1 | | 1 | | | 1 | | | 1 | | | | | 2 | 2
CVA, Isch | | | 1 | ↓L:2 | 5 | 2 | 1 | 1 | 2 | | 1 | 2 | | | 1 | | | | | 2 | 3
CVA, Tot | | 1 | 1 | L:7 | 4 | 2 | | | 1 | | | 1 | | | 1 | | | | 1 | 3 | 2
SCD | | 1 | 1 | H:9 | 1 | | 1 | | 1
Vent Arrh | | | | 1 | | | | | | | | | | | | | | | 1

Table summarizing the number of studies that report on each evaluation of a type of omega–3 fatty acid (n-3 FA) and outcome, by study design. High (H), moderate (M), and low (L) strength of evidence for each n-3 FA-outcome pair are indicated by the respective letters (and bold font). Bold upright (nonitalic) script indicates evidence of no effect or association; bold italic text indicates evidence of a reduced risk of the outcome with higher n-3 FA intake (also indicated by a down arrow). n-3 FA-outcome pairs with regular font had insufficient evidence. Blank cells indicate no studies of the given design type reported on the n-3 FA-outcome pair.

Abbreviations: ACS = acute coronary syndrome, AFib = atrial fibrillation, ALA = alphalinolenic acid, Card = cardiac, CHD = coronary heart disease, CHF = congestive heart failure, CVA = cerebrovascular accident (stroke), CVA Dth = stroke death, CVA, Hem = hemorrhagic stroke, CVA, Isch = ischemic stroke, CVA, Tot = total stroke, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HTN = incident hypertension, MACE = major adverse cardiac event, MI = myocardial infarction, MvA = direct comparison of marine oil and ALA (in randomized controlled trials), n-3 FA = omega–3 fatty acids, OB = observational studies of n-3 FA biomarkers, OI = observational studies of n-3 FA intake, R = randomized controlled trials, Revasc = revascularization, SCD = sudden cardiac death, Vent Arrh = ventricular arrhythmia.

Table 2 Enumeration of studies by intermediate outcome and n-3 FA

Outcome | Total n-3 FA | | | Marine Oil | | | EPA | | | DHA | | | DPA | | | SDA | | | ALA | | | MvA
| R | OI | OB | R | OI | OB | R | OI | OB | R | OI | OB | R | OI | OB | R | OI | OB | R | OI | OB | R
Total (including clinical outcomes) | 2 | 8 | 3 | 55 | 21 | 8 | 1 | 8 | 9 | 1 | 8 | 10 | | 2 | 6 | 2 | | 1 | 6 | 12 | 7 | 3
SBP | 2 | | | H:29 | | | 2 | | 1 | M:3 | | 1 | | | 1 | | | | M:4 | | | 2
DBP | 2 | | | H:28 | | | 2 | | 1 | M:3 | | 1 | | | 1 | | | | M:4 | | | 2
MAP | | | | 3 | | | 2
LDL-c | 2 | | | ↑H:39 | | | 2 | | | 3 | | | | | | 2 | | | 5 | | | 2
HDL-c | 2 | | | ↓H:34 | | | 2 | | | 3 | | | | | | 2 | | | 5 | | | 2
Tg | 2 | | | ↓H:41 | | | 2 | | | 2 | | | | | | 2 | | | 5 | | | 2
Total:HDL-c | 2 | | | ↓H:8 | | | 1 | | | | | | | | | 1 | | | 3
LDL:HDL-c | | | | 3 | | | | | | | | | | | | 1 | | | 1

Table summarizing the number of studies that report on each evaluation of a type of omega–3 fatty acid (n-3 FA) and outcome, by study design. High (H), moderate (M), and low (L) strength of evidence for each n-3 FA-outcome pair are indicated by the respective letters (and bold font). Bold upright (nonitalic) script indicates evidence of no effect or association; bold italic text indicates evidence of a reduced (↓) or increased (↑) cardiovascular risk associated with the outcome with higher n-3 FA intake (as indicated by the direction of the arrow). n-3 FA-outcome pairs with regular font had insufficient evidence. Blank cells indicate no studies of the given design type reported on the n-3 FA-outcome pair.

Abbreviations: ALA = alphalinolenic acid, DBP = diastolic blood pressure, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, LDL:HDL-c = LDL-c to HDL-c ratio, LDL-c = low density lipoprotein cholesterol, MAP = mean arterial pressure, MvA = direct comparison of marine oil and ALA (in randomized controlled trials), n-3 FA = omega–3 fatty acids, OB = observational studies of n-3 FA biomarkers, OI = observational studies of n-3 FA intake, R = randomized controlled trials, SBP = systolic blood pressure, Tg = triglycerides, Total:HDL-c = total cholesterol to HDL-c ratio.

## Major Adverse Cardiovascular Events

### Randomized Controlled Trials

Ten RCTs reported the composite outcome major adverse cardiac event (MACE) (Table 3).67, 90, 96, 115, 119, 121, 123, 146, 157, 160 Of these, three studies were conducted in a total of 31,713 people at risk of CVD including dyslipidemia,90, 115 or a combination of various risk factors.160 Eight studies were conducted in a total of 35,095 people with CVD, defined as a history of CVD,123 a history of myocardial infarction (MI),67, 119, 121 acute MI,90 previous coronary heart disease (CHD),90 peripheral artery disease at any time,90 persistent atrial fibrillation (AFib),157 heart failure,96 or, in one study, either a history of CVD or of diabetes.146 None of the RCTs were conducted in a generally healthy population. One study analyzed MACE as a primary outcome (Roncaglioni 2013); however, the trial changed the primary outcome at 1 year from CVD death due to a low event rate.160

Table 3 Major adverse cardiovascular events (composite outcome): RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs Placebo
Yokoyama 2007 17398308^*^ Japan | At risk (dyslipidemia; 19.5% with CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 262/9326, 2.8% | 324/9319, 3.5% | HR 0.81 (0.69, 0.95) | 0.011
| At risk | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 104/7503 1.4% | 127/7478 1.7% | HR 0.81 (0.66, 1.00) | 0.048
Einvik 2010 20389249^†^ Scandinavia | At risk | EPA+DHA+ diet intervention | 2.02 g/d (Marine oil) [E:D 1.4] | Placebo+diet intervention | 0 (Corn oil) | 3 y | >90% of the tablets were taken based on pharmacy records, and verified by biomarkers | 32/282, 11% | 36/281, 13% | HR 0.89 (0.55, 1.44) | 0.624
Roncaglioni 2013 23656645^‡^ Italy | At risk | EPA+DHA | 0.85 g/d (Marine oil) [E:D 0.9–1.5] | Placebo | 0 (Olive oil) | 5 y | Monitored by self-report but compliance level was not reported | 733/6239, 12% | 745/6266, 12% | HR 0.98 (0.88, 1.08) | 0.64
Bosch 2012 22686415^§^ Canada | CVD (or diabetes) | EPA+DHA | 0.84 g/d (Marine oil) [E:D 1.24] | Placebo | 0 (Olive oil) | 6+ y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 1034/6281, 16.5% | 1017/6255, 5.1% | HR 1.01 (0.93, 1.10) | 0.81
Galan 2010 21115589^¶^ France | CVD | EPA+DHA | 0.6 g/d (Marine oil) [E:D 2] | Placebo | 0 (nd) | 4.7 y | Patient reported (86% reported they took ≥80% of allocated treatment) | 81/1253, 7% | 76/1248, 6% | HR 1.08 (0.79, 1.47) | 0.64
Macchia 2013^#^ 23265344 | CVD | EPA+DHA | 0.850–0.882 g/d (Marine oil) [E:D 0.5] | Placebo | 0 (Olive oil) | 1 y | nd | 16/289, 6% | 20/297, 7% | HR 0.86 (0.44, 1.66)
Rauch 2010 21060071 Germany | CVD | EPA+DHA | 0.46 g EPA, 0.38 g DHA (Marine oil) [E:D=1.2] | Placebo | 0 (Olive oil) | 1 y | Pill counts at 3 months and 12 months (≥70% of study period) | 182/1752, 10.4% | 149/1701, 8.8% | OR 1.21 (0.96, 1.52) | 0.10
Tavazzi 2008 18757090^**^ Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 (nd) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 1981/3494, 57% | 2053/3481, 57% | HR 0.92 (0.85, 0.999) | 0.009
Kromhout 2010 20929341^††^ Netherlands | CVD | EPA+DHA (±ALA) | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±ALA) | 0; 2 g/d ALA (Placebo margarine = oleic acid; Plant oil) | 3.4 y | 90% of the patients adhered fully to the protocol; verified by biomarkers | 336/2424, 14.0% | 335/2433,13.8% | HR 1.01 (0.87, 1.17) | 0.93
Nilsen 2001 2001 11451717 Norway | CVD | EPA+DHA | EPA-DHA 3.4–3.528 g/d (Marine oil) [E:D=0.5] | Placebo | 0 (Corn oil) | median 2.4 y | nd | 52/150, 34.7% | 49/150, 32.7% | OR 1.09 (0.68, 1.77)
Yokoyama 2007 17398308^*^ Japan | CVD (previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 158/1823 8.7% | 197/1841 10.7% | HR 0.82 (0.63, 1.06) | 0.132
| CVD (PAD at any time) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 9/117 7.7% | 18/106 17% | HR 0.44 (0.19, 0.97) | 0.041
ALA vs. Placebo
Kromhout 2010 20929341^††^ Netherlands | CVD | ALA (±EPA+DHA) | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±EPA+DHA) | 0; 0.4 g/d EPA−DHA (placebo = oleic acid; Marine oil) [E:D 3:2] | 3.4 y | 90% of the patients adhered fully to the protocol; verified by biomarkers | 319/2409, 13.2% | 352/2428,14.5% | HR 0.91 (0.78, 1.05) | 0.20

* Sudden cardiac death, fatal and nonfatal myocardial infarction, and other nonfatal events including unstable angina pectoris, angioplasty, stenting, or coronary artery bypass grafting

† Fatal or nonfatal sudden cardiac arrest, myocardial infarction, percutaneous coronary intervention, coronary artery bypass grafting, cerebral stroke, surgery on abdominal aortic aneurysm, or peripheral revascularization procedures

‡ Death from cardiovascular causes or hospital admission from cardiovascular causes

§ Myocardial infarction, stroke, or death from cardiovascular causes

¶ Nonfatal myocardial infarction, ischemic stroke, or death from cardiovascular disease (including fatal myocardial infarction, stroke, sudden death, aortic dissection, cardiac failure, or other fatal event defined by the medical committee as having a cardiovascular cause)

# First occurrence of either all-cause mortality, nonfatal stroke, nonfatal acute myocardial infarction, systemic embolism, heart failure development, or severe bleeding

** Death from any cause or admission to the hospital for cardiovascular reasons

†† Fatal CVD, nonfatal myocardial infarction, nonfatal cardiac arrest, and nonfatal stroke

Abbreviations: ALA = alphalinolenic acid, CHD = coronary heart disease, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n3 FA = omega-3 fatty acids, n6:3 = omega-6 to omega-3 fatty acid ratio, OR = odds ratio, RCT = randomized controlled trial.

MACE was defined differently for each study, but was generally a composite of all-cause death,96, 121, 157 cardiovascular (CV) death,123, 146, 160 cardiac death,67, 90 fatal and nonfatal MI,67, 90, 115, 119, 123, 146 cardiac arrest,115, 119 unstable angina,67, 90 hospitalization for CV reasons,96, 157, 160 stroke,115, 119, 121, 123, 146 coronary artery bypass grafting,90, 115 and/or other CV procedures.67, 90, 115, 121

#### Marine Oil Versus Placebo

Meta-analysis of the 10 RCTs of marine oil versus placebo yielded a nonsignificant summary effect size for risk of MACE: hazard ratio (HR) = 0.96 (95% confidence interval [CI] 0.91 to 1.02) (Figure 6).67, 90, 96, 115, 119, 121, 123, 146, 160, 166

Figure 6 Major adverse cardiovascular events: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, FA = fatty acid(s), n/N = number with outcome/number analyzed, n-3 FA = omega-3 fatty acids, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure demonstrates that a meta-analysis of the eight randomized control trials of marine oil versus placebo yielded a just-significant summary effect size for risk of major cardiovascular events. Major Adverse Cardiovascular Events: HR=0.96 (95% CI 0.91, 1.02; P=0.188)

##### At-Risk-for-CVD Population

Among people at risk of CVD, one trial compared EPA ethyl ester (combined with statin) with control (statin alone) in 18,645 participants with dyslipidemia (19.5% with CHD)90 and two studies compared marine oil (EPA+DHA) to placebo (olive oil or corn oil) in a total of 13,068 participants with dyslipidemia or multiple CVD risk factors.115, 160 In the study of EPA ethyl ester, the dose of EPA was 1.8 g/d; in the other two studies the doses of EPA+DHA were 0.85 and 2.02 g/d with EPA to DHA ratio either 0.9 or 1.5. Compliance was monitored and the adherence level was greater than 90 percent in one study,115 but not reported in the other two studies. The duration of followup ranged from 3 to 5 years.

In one RCT, EPA supplementation (1.8 g/d) had a significant additive effect (to statin therapy) on reducing the risk of MACE (including sudden cardiac death [SCD], fatal and nonfatal MI, and nonfatal unstable angina pectoris, angioplasty, stenting, or coronary artery bypass grafting) compared with statin alone after 5 years of followup, both when including the 19.5 percent of patients with CHD (HR 0.81; 95% CI 0.69 to 0.95) and when considering the subpopulation with dyslipidemia only (HR 0.81; 95% CI 0.66 to 1.00).90 The other two trials found that EPA+DHA supplementation (0.85 and 2.02 g/d) did not significantly reduce the risk of MACE (heterogeneous definitions) compared with placebo (HR 0.98, 95% CI 0.88 to 1.08; HR 0.89, 95% CI 0.55 to 1.44)

Subgroup meta-analysis yielded a summary HR of 0.90 (95% CI 0.77 to 1.05) for people at risk for CVD.

##### CVD Population

Among people with CVD, eight RCTs (seven parallel design, one a 2-by–2 factorial RCT) evaluated MACE. Six simple RCTs compared marine oil (EPA+DHA) to placebo (olive oil in two studies and sources not reported in the other two studies) in a total of 22,259 participants with diabetes and history of CVD, all CVD, heart failure or previous persistent AFib.96, 123, 146, 157 The 2-by–2 factorial RCT compared the effects of a margarine supplemented with EPA+DHA alone (0.4 g/d), a combination of both EPA+DHA and ALA margarines, and ALA alone (2 g/d) with placebo margarine (oleic acid) in 4837 participants with a history of MI.119 (The 2-by–2 factorial trial reported only analyses of EPA+DHA vs. placebo and ALA vs. placebo.) One trial compared 1.8 g/d EPA ethyl ester plus statin with statin alone in two populations: 3,664 with previous CHD and 223 with peripheral artery disease at any time.90

Among the seven trials that compared marine oil (EPA+DHA) to placebo, the doses of EPA+DHA used ranged from 0.4 to 3.5 g/d, and the EPA to DHA ratio ranged from 0.5 to 2. Reported in five studies, the compliance ranged from 70 to 90 percent. The duration of followup ranged from 1 to >6 years. Six of the seven trials found that EPA+DHA supplementation did not significantly reduce the risk of MACE (heterogeneous definitions) compared with placebo (HR or odds ratio [OR] ranging from 0.88 to 1.21).67, 119, 121, 123, 146, 157 The seventh trial found that EPA+DHA ethyl ester supplementation significantly reduced the risk of MACE (defined as death from any cause or admission to the hospital for CV reasons) compared with placebo in 6975 participants with heart failure (HR 0.92, 95% CI 0.85 to 0.99).96 In the trial that compared EPA plus statin with statin alone, the analysis of patients with previous CHD found no significant additive effect of EPA supplementation on the risk of MACE (HR 0.82; 95% CI 0.63 to 1.06), while the analysis of patients with peripheral artery disease at any time did find a significant additive effect (HR 0.44; 95% CI 0.19 to 0.97).90

Subgroup meta-analysis yielded a summary HR of 0.98 (95% CI 0.92 to 1.05) for people with CVD.

#### ALA Versus Placebo

##### CVD Population

In the 2-by–2 factorial RCT, the groups that received ALA margarines had no significant difference in the risk of MACE compared with placebo margarines (HR 0.92; 95% CI 0.73 to 1.11).119

#### RCT Subgroup Analyses

Three RCTs reported subgroup analysis for MACE (Table 4). In one trial, EPA+DHA (vs. placebo) lowered the risk of MACE in women (HR=0.82) in contrast with the effect in men (HR 1.04) and the difference between women and men was statistically significant (P interaction 0.04).160 The second trial found no difference in effect of EPA versus placebo between men and women (HR 0.76 vs 0.87, P-interaction 0.43).90 This study analyzed several other subgroups, but found no significant differences in effect between any subgroups. These included age ≥61 versus <61 years, body mass index ≥24 versus <24 kg/m^2^, triglycerides (Tg) ≥270 versus <270 mg/dL, Tg ≥150 versus <150 mg/dL, high density lipoprotein cholesterol (HDL-c) ≥58 versus <58 mg/dL, low density lipoprotein cholesterol (LDL-c) ≥181 versus <181 mg/dL, history of CHD versus no CHD, smoker versus nonsmoker, diabetes versus no diabetes, and hypertension versus no hypertension.90 The third trial reported an incomplete and unclear analysis of many subgroup analyses for both EPA+DHA versus placebo and ALA versus placebo. No interaction analyses were reported, but near-significant effects (P<0.10) of ALA on MACE reduction were seen for those <70 years old (HR 0.83, P=0.08) as opposed to older subjects (HR 1.00, P=0.98) and for women (HR 0.73, P=0.07) as opposed to men (HR 0.96, P=0.60). No significant effects of ALA were found in all subgroups based on time since MI, baseline fish intake, baseline EPA+DHA intake, and history of diabetes. No significant effects of EPA+DHA were found in all subgroups analyzed.

Table 4 Major adverse cardiovascular events (composite outcome): Subgroup analyses, randomized trials

Study | Population | Subgroups | n-3 FA | Comparator | N Total | P difference | Difference | Favors
Roncaglioni 2013 23656645 Italy | At risk | Men vs. women | EPA+DHA | Placebo | 12505 | 0.04 | HR 1.04 vs. 0.82 | Women
Yokoyama 2007 17398308 Japan | At risk | Men vs. women | EPA | Placebo | 18645 | 0.43
Yokoyama 2007 17398308 Japan | At risk | Age ≥61 vs. <61 y | EPA | Placebo | 18645 | 0.57
Yokoyama 2007 17398308 Japan | At risk | Body mass index ≥24 vs. <24 kg/m^2^ | EPA | Placebo | 18645 | 0.88
Yokoyama 2007 17398308 Japan | At risk | Tg ≥270 vs. <270 mg/dL | EPA | Placebo | 18645 | 0.46
Yokoyama 2007 17398308 Japan | At risk | Tg ≥150 vs. <150 mg/dL | EPA | Placebo | 18645 | 0.75
Yokoyama 2007 17398308 Japan | At risk | HDL-c ≥58 vs. <58 mg/dL | EPA | Placebo | 18645 | 0.26
Yokoyama 2007 17398308 Japan | At risk | LDL-c ≥181 vs. <181 mg/dL | EPA | Placebo | 18645 | 0.83
Yokoyama 2007 17398308 Japan | At risk | CHD vs. no CHD | EPA | Placebo | 18645 | 0.95
Yokoyama 2007 17398308 Japan | At risk | Smoker vs. nonsmoker | EPA | Placebo | 18645 | 0.89
Yokoyama 2007 17398308 Japan | At risk | Diabetes vs. no diabetes | EPA | Placebo | 18645 | 0.62
Yokoyama 2007 17398308 Japan | At risk | HTN vs no HTN | EPA | Placebo | 18645 | 0.57
Yokoyama 2007 17398308 Japan | At risk | PAD vs no PAD at baseline | EPA | Placebo | 18645 | 0.16
Kromhout 2010 20929341 Netherlands | CVD | ≥70 vs. <70 y | EPA+DHA | Placebo or ALA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Men vs. women | EPA+DHA | Placebo or ALA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Time since MI ≥3.7 vs. <3.7 y | EPA+DHA | Placebo or ALA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Baseline fish intake ≥5 vs. <5 g/d | EPA+DHA | Placebo or ALA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Baseline EPA+DHA intake ≥50 vs. <50 mg/d | EPA+DHA | Placebo or ALA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Diabetes vs. no diabetes | EPA+DHA | Placebo or ALA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Statin vs. no statin | EPA+DHA | Placebo | 4153 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | ≥70 vs. <70 y | ALA | Placebo or EPA+DHA | 4837 | NS older P=0.08 younger | HR 1.00 vs. 0.83 | <70 y (possibly)
Kromhout 2010 20929341 Netherlands | CVD | Men vs. women | ALA | Placebo or EPA+DHA | 4837 | NS men P=0.07 women | HR 0.96 vs. 0.73 | Women (possibly)
Kromhout 2010 20929341 Netherlands | CVD | Time since MI ≥3.7 vs. <3.7 y | ALA | Placebo or EPA+DHA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Baseline fish intake ≥5 vs. <5 g/d | ALA | Placebo or EPA+DHA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Baseline EPA+DHA intake ≥50 vs. <50 mg/d | ALA | Placebo or EPA+DHA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Diabetes vs. no diabetes | ALA | Placebo or EPA+DHA | 4837 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Statin vs. no statin | ALA | Placebo | 4153 | NS both subgroups
Kromhout 2010 20929341 Netherlands | CVD | Statin vs. no statin | EPA+DHA+ALA | Placebo | 4153 | NS statin, 0.051 no statin | HR 1.02 vs. 0.46 | No statin (possibly)

Abbreviations: ALA = alphalinolenic acid, CHD = coronary heart disease, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, HR = hazard ratio, HTN = hypertension, LDL-c = low density lipoprotein cholesterol, MI = myocardial infarction, n-3 FA = omega-3 fatty acids, NS = not significant, PAD = peripheral artery disease, Tg = triglycerides.

Meta-regression of the marine oil trials found no significant interaction between n-3 FA dose (P=0.15), followup time (P=0.49), or between at risk and CVD populations (P=0.63)

### Observational Studies

Seven studies evaluated variously defined MACE (or total CVD events), composite outcomes that combined cardiac, coronary, and cerebrovascular events (Appendix F, Major adverse cardiac events section; Figure 7). Each study used its own combination of diagnoses. The studies included generally healthy adults or, in one instance, “at risk” adults with hypercholesterolemia on low dose statins.50, 101, 122, 126, 137, 155, 171, 183 Followup durations ranged from 4 to about 20 years.

Figure 7 n-3 FA associations with major adverse cardiovascular events: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. Where 95% confidence intervals (vertical lines) are missing, these were not reported in the studies.

White triangles = healthy adults, black circles = adults with dyslipidemia (at risk), white squares = healthy males, black squares = healthy females.

Abbreviations: AA = arachidonic acid, ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA= omega-3 fatty acids.

This figure presents 18 different plots the hazard ratio of variously defined major adverse cardiovascular outcomes, composite outcomes that combined cardiac, coronary, and cerebrovascular events and the associations or interactions with exposure to omega-3 fatty acids. The measures of omega-3 fatty acids include total omega-3 fatty acid combined, EPA+DHA or EPA+DHA+DPA intake, omega-3 fatty acid biomarkers, EPA biomarkers, DHA biomarkers, DPA biomarkers, and combined EPA+DHA biomarkers. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

Five studies evaluated n-3 FA intake (Danish National Birth Cohort, Health Professional Follow-up Study, Malmo Diet and Cancer, MESA, Physician’s Health Study).50, 101, 137, 155, 171, 183

Three studies analyzed intake of total n-3 FA combined (Figure 7, plot # 17 & 18). The Physician’s Health Study (in healthy men)50, 155 and the Malmo Diet and Cancer study (in healthy adults)183 both found no association with MACE at 4 and 14 years of followup. In contrast the Danish National Birth Cohort (in healthy women who were pregnant at the time of enrollment) found significantly increased risks of cerebrovascular, ischemic heart disease, or hypertensive disease hospitalization after 12 years on those with higher n-3 FA intake (Figure 7, plot #18).137 However, no clear intake threshold was found.

The Malmo Diet and Cancer and MESA studies found no association between ALA intake and MACE at 10 and 14 years of followup (Figure 7, plots #1 & 2).171, 183

MESA found an overall significant association between both EPA, DHA, and DPA intake (separately) and combined ischemic coronary events, cardiac arrest, stroke, and CVD death in healthy adults after 10 years of followup (Figure 7, plots #4, 8, 14).171 For DHA intake, the association was near-significant (P<0.10) for the uppermost quartile with a median dose of 0.15 g/d, for DPA 0.02 g/d, and for EPA 0.04 g/d.

Three studies evaluated combined EPA+DHA or EPA+DHA+DPA intake (Figure 7, plots # 11 & 12). The Health Professionals Follow-up Study (evaluating EPA+DHA)101 and Malmo Diet and Cancer study (evaluating EPA+DHA+DPA)183 found no significant association at 14 and 18 years of followup. MESA found an overall statistically-significant lower risk of combined ischemic coronary events, cardiac arrest, stroke, and CVD death in healthy adults after 10 years of followup with higher intake of EPA+DHA+DPA.171 The association was near-significant for the highest quartile with a median intake dose of about 0.3 g/d (P<0.10).

#### n-3 FA Biomarkers

Five studies evaluated n-3 FA biomarkers (JELIS, Physician’s Health Study, Scottish Heart Health Extended Cohort Study, MESA, Hisayama).50, 122, 126, 155, 168, 171

The Physician’s Health Study and MESA found no associations between erythrocyte or phospholipid ALA levels and MACE (Figure 7, plot # 3, erythrocyte n-3 FA associations not plotted because they were not analyzed by quantile).50, 155, 171

Four studies evaluated EPA biomarkers, two of which found statistically significant associations with MACE (Figure 7, plots #10 & 16). The Physician’s Health Study found no significant association between erythrocyte EPA and MACE in healthy men.50, 155 Hisayama found no significant association between plasma EPA and MACE in healthy patients.168 MESA, in contrast, found a significant association between higher phospholipid EPA and lower MACE (Figure 7, plot #15).171 In a population of people with dyslipidemia on low-dose statins, JELIS also found a significant association between higher plasma EPA and lower risk of MACE (Figure 7, plot #10).122

Five studies evaluated DHA biomarkers, with heterogeneous findings (Figure 7, plots #6 and 7; other biomarkers not plotted due to insufficient reported data or not quantile analysis). Hisayama, JELIS and the Physician’s Health Study found no significant associations with plasma or erythrocyte DHA.50, 122, 155, 168 The Scottish Heart Health Extended Cohort Study, though, found that higher adipose tissue DHA levels were associated with reduced risk of MACE at about 20 years of followup,126 and the MESA study also found reduced risk of MACE associated with higher phospholipid DHA levels at 10 years of followup.171

Three studies evaluated DPA biomarkers, one of which found a significant association (Figure 7, plot #9; other biomarkers not plotted due to insufficient reported data or not quantile analysis). The Scottish Heart Health Extended Cohort Study found that higher adipose tissue DPA levels were associated with lower risk of MACE at about 20 years of followup.126 In contrast, the Physician’s Health Study and MESA found no significant associations with erythrocyte or phospholipid DPA.50, 155, 171

The Physician’s Health Study also found no significant association between erythrocyte SDA and MACE.50, 155

Two studies evaluated combined EPA+DHA biomarkers (Figure 7, plot #13). The Physician’s Health Study found no association with erythrocyte EPA+DHA,50, 155 but MESA found that higher phospholipid EPA+DHA levels were associated with lower risk of MACE at 10 years of followup.171

#### Observational Study Subgroup Analyses

Only MESA reported subgroup analyses.171 In comparisons of n-3 FA biomarker associations with MACE by race, the study found no significant differences in associations for EPA, DHA, and EPA+DHA+DPA levels, but whites (HR=0.41) and Chinese (HR=0.30) had significantly stronger associations than African Americans (HR=1.51) and Hispanics (HR=1.33; P interaction = 0.01).

## CVD Death (Including Stroke)

### Randomized Controlled Trials

Seven RCTs reported total CVD death (Table 5).67, 70, 96, 115, 119, 146, 160 Of these, two were conducted in a total of 13,068 people at risk of CVD defined as dyslipidemia or at least four CVD risk factors,115, 160 and the other five in a total of 36,002 people with CVD including diabetes, history of CVD, MI or heart failure.67, 70, 96, 119, 146 None of the trials analyzed CVD death as a primary outcome, but Roncaglioni 2013 reported that it was the a priori primary outcome; the primary outcome was changed to MACE at 1 year due to a low event rate for CVD death).160

Table 5 CVD death (including stroke): RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA (±ALA) | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±ALA) | 0; 2 g/d ALA (Placebo margarine = oleic acid; Plant oil) | 3.4 y | 90% of the patients adhered fully to the protocol; verified by biomarkers | 80/2424, 3.3% | 82/2433, 3.4% | HR 0.98 (0.72, 1.33) | 0.89
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | ≤0.85 g (Marine oil) [E:D 0.9–1.5] | Placebo | 0 (Olive oil) | 5 y | Monitored by self-report but compliance level was not reported | 142/6239, 2.3% | 137/6266, 2.2% | HR 1.03 (0.82, 1.30) | 0.8
Einvik 2010 20389249 Norway | At risk | EPA+DHA+ diet intervention | 2.02 g/d (Marine oil) [E:D 1.4] | Placebo+ diet intervention | 0 (Corn oil)) | 3 y | >90% of the tablets were taken based on pharmacy records, and verified by biomarkers | 7/282, 2% | 11/281, 4% | OR 0.62 (0.24, 1.64)^c^ | nd
Bosch 2012 22686415 Canada | CVD | EPA+DHA | 0.84 g/d (Marine oil) [E:D 1.24] | Placebo | 0 (Olive oil) | 6+ y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 574/6281, 9.1% | 581/6255, 9.3% | HR 0.98 (0.87,1.10) | 0.72
Marchioli 2002 11997274 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Marine oil) [E:D 0.5] | No intervention | nd | 3.5 y | Followup (adherence was 72.5% at the end of study) | 310/5666, 5.5% | 370/5668, 6.5% | RR 0.70 (0.56, 0.86) | <0.001
Nilsen 2001 2001 11451717 Norway | CVD | EPA+DHA | EPA−DHA 3.4–3.528 g/d (Marine oil) [E:D=0.5] | Placebo | 0 (Corn oil) | median 2.4 y | nd | 16/150, 11% | 12/150, 8% | 1.37 (0.63, 3.01)
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 (nd) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 712/3494, 20.4% | 765/3481, 22.0% | Adjusted HR 0.90 (0.81, 0.99)^b^ | 0.045
ALA vs. Placebo
Kromhout 2010 20929341 Netherlands | CVD | ALA (±EPA+DHA) | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±EPA+DHA) | 0; 0.4 g/d EPA&DHA (placebo = oleic acid; Marine oil) [E:D 3:2] | 3.4 y | 90% of the patients adhered fully to the protocol; verified by biomarkers | 78/2409, 3.2% | 84/2428, 3.5% | HR 0.94 (0.69, 1.27) | 0.67

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, OR = odds ratio, PMID = PubMed Identification number, RCT = randomized controlled trial, RR = relative risk.

#### Marine Oil Versus Placebo

Meta-analysis of the seven RCTs of marine oil versus placebo yielded a nonsignificant summary effect size for risk of CVD death: HR=0.92 (95% CI 0.82 to 1.02) (Figure 8).67, 70, 96, 115, 119, 146, 160

Figure 8 CVD death: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, n/N = number with outcome/number analyzed, n-3 FA = omega-3 fatty acids, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure demonstrates a meta-analysis of seven randomized control trials that examine the effect of marine oil versus placebos. These studies yielded a near-significant summary effect size for risk of cardiovascular disease mortality. Overall p=0=0.134.

##### At-Risk-for-CVD Population

Among people at risk of CVD, two studies compared marine oil (EPA+DHA) to placebo (either olive oil or corn oil) in a total of 13,068 participants.115, 160 The doses of EPA and DHA were less than 0.85 and 2.02 g/d, and the EPA to DHA ratio ranged from 0.9 to 1.5. Compliance was high (>90%) in one study115 and not reported (although monitored by self-report) in another study.160 The durations of followup were 3 and 5 years. Both studies found that EPA+DHA supplementation did not significantly reduce CVD death compared with placebo (HR 1.03, 95% 0.82 to 1.30; OR 0.62, 95% CI 0.24 to 1.64).

Subgroup meta-analysis yielded a summary HR of 0.99 (95% CI 0.77 to 1.28) for people at risk for CVD.

##### CVD Population

Among people with CVD, five trials compared marine oil (EPA+DHA) to placebo (olive oil in one study, corn oil in another, and source was not reported in one study),67, 96, 146 to no intervention,70 and in a factorial study with ALA,119 in a total of 36,002 participants. The dose of EPA+DHA ranged from 0.84 to 3.5 g/d, and the EPA to DHA ratio ranged from 0.5 to 1.24. Compliance ranged from about 70 to 88 percent. The mean duration of followup ranged from 2.4 to more than 6 years. Two of the five studies found that EPA+DHA supplementation significantly reduced the CVD death compared with no intervention or placebo in 11,334 participants with MI (RR 0.70, 95% CI 0.56 to 0.86)70 and in 6975 participants with heart failure (adjusted HR 0.91, 95% CI 0.81 to 0.99).96 Two studies did not find a difference in the risk of CVD death between EPA+DHA and placebo in 12,536 participants with diabetes or history of CVD (HR 0.98, 95% CI 0.87 to 1.10).146 and in 300 participants with acute MI (HR 1.37, 95% CI: 0.63 to 3.01).67 The fifth study was the 2-by–2 factorial RCT described under Major Adverse CVD Events that compared EPA+DHA, EPA+DHA and ALA, ALA, and oleic acid margarines in 4837 participants with MI.119. During a mean of 3.4 years of followup, EPA+DHA containing margarines had no significant effect on CVD death compared with the ALA alone or placebo margarines (HR 0.98; 95% CI 0.72 to 1.33).

Subgroup meta-analysis yielded a summary HR of 0.90 (95% CI 0.79 to 1.03) for people with CVD.

#### ALA Versus Placebo

##### CVD Population

In the 2-by–2 factorial RCT, the groups that received ALA margarines had no significant difference in the risk of MACE compared with placebo margarines (HR 0.94; 95% CI 0.69 to 1.27).119

#### RCT Subgroup Analyses

Three RCTs reported subgroup analysis for CVD death (Table 6). The same 2-by–2 factorial RCT analyzed subgroups based on history of diabetes.119 For patients with diabetes, EPA+DHA had a nonsignificant reduction in CVD death risk (HR=0.60, P=0.08) in contrast to those without diabetes (HR=1.21, P=0.32); no test for interaction was reported. The effect of ALA on CVD death was similarly nonsignificant in both patients with diabetes (HR=0.87, P=0.63) and those without diabetes (HR=0.97, P=0.87).

Table 6 CVD death (including stroke): Subgroup analyses, randomized trials

Study Year PMID Region | Population | Subgroups | n-3 FA | Comparator | N Total | P difference | Difference | Favors
Bosch 2012 22686415 Canada | CVD | Glargine vs no glargine | EPA+DHA | Placebo | 12536 | 0.66
| CVD | Age >= 65 vs < 65 | EPA+DHA | Placebo | 12536 | 0.72
| CVD | Prior CVD event vs. no prior CVD event | EPA+DHA | Placebo | 12536 | 0.70
| CVD | High heart rate (>=69 beats/min) vs low HR (<69 beats/min | EPA+DHA | Placebo | 12536 | 0.77
| CVD | Statin vs no statin | EPA+DHA | Placebo | 12536 | 0.72
| CVD | Beta blocker use vs. no beta blocker use | EPA+DHA | Placebo | 12536 | 0.79
| CVD | n-3 FA intake in tertiles (lowest to highest) | EPA+DHA | Placebo | 12536 | 0.18
| CVD | Tg in tertiles (lowest to highest) | EPA+DHA | Placebo | 12536 | 0.48
Kromhout 2010 20929341 Netherlands | CVD | Diabetes vs. no diabetes | EPA+DHA | Placebo or ALA | 4837 | 0.08 diabetes, 0.32 no diabetes | 0.60 vs. 1.21 | Diabetes (possibly)
| CVD | Diabetes vs. no diabetes | ALA | Placebo or EPA+DHA | 4837 | NS both subgroups

Abbreviations: ALA = alphalinolenic acid, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, NS = not significant, PMID = PubMed Identification number, Tg = triglycerides.

Bosch 2012 analyzed subgroups based on glargine use, age over 65, prior CVD events, heart rate over 69 beats per minute, statin use, beta blocker use, tertiles of n-3 FA intake, and triglyceride tertiles, none of which found significant interactions or significant effects of EPA+DHA on CVD death.

Meta-regression of the marine oil trials found no significant interaction between n-3 FA dose (P=0.59), followup time (P=0.33), or between at risk and CVD populations (P=0.75)

### Observational Studies

Eight studies evaluated the association between n-3 FA intake or biomarkers and total CVD death in healthy adults from 4 to 31 years of followup (median 11 years) (Appendix F Death from cardiovascular disease section; Figure 9).47, 50, 72, 95, 98, 159, 162, 175, 186 The studies had heterogeneous findings regarding associations between higher n-3 FA intake or biomarker levels and lower risk of CVD death.

Figure 9 n-3 FA associations with CVD death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. Where 95% confidence intervals (vertical lines) are missing, these were not reported in the studies. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females.

Abbreviations: ALA = alphalinolenic acid, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

Fifteen plots represent associations between omega-3 fatty acid exposure and hazard ratio of the outcome-death in longitudinal observational studies. The measures of omega-3 fatty acids include intake, total omega-3 fatty acid intake, ALA intake EPA intake, DHA intake, and EPA+DHA intake. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

Eight studies evaluated n-3 FA intake (JACC, MRFIT, NIPPON DATA80, Physician’s Health Study, Shanghai Women’s and Men’s Health Studies, Singapore Chinese Healthy Study, Takayama, VITAL).47, 50, 72, 98, 155, 162, 170, 175, 176

Four studies evaluated total n-3 FA intake (JACC, NIPPON DATA80, Physician’s Health Study, Singapore Chinese Health Study) (Figure 9, plots #31 & 32).50, 98, 155, 170, 175, 176 JACC found a significant association between higher total n-3 FA intake (combined) and lower CVD death risk in healthy adults after about 13 years of followup, with a significant association occurring in quantile with median of 2 g/d or higher.98 JACC and NIPPON DATA80, however, found no significant associations at 4 and 24 years of followup.98, 175 The Singapore Chinese Health Study found no significant association between higher total n-3 FA intake and lower CVD death risk in CVD adults, but found a significant association in healthy adults (P=0.006).170

Three studies evaluated ALA intake with conflicting results (Figure 9, plots #19 & 20). MRFIT found a significant association between higher ALA intake (measured as percent Kcal) and lower CVD risk at about 10 years (particularly in quartiles with median intake greater than about 0.7% Kcal); when ALA intake was measured as g/d, the association was similar, but nonsignificant (P=0.10). The Cardiovascular Health Study found no association at 12 years of followup.47 The Singapore Chinese Health Study found no significant association between higher ALA intake and lower CVD death risk in CVD adults, but found a significant association in healthy adults (P<0.001).170

Two studies evaluated EPA intake, also with conflicting results (Figure 9, plots #28 & 29). NIPPON DATA80 found no association at 24 years of followup,175 but the Shanghai Women’s and Men’s Health Studies found a significant association between higher EPA intake and lower risk of CVD death among men (at about 6 years of followup) and women (at about 12 years), combined (with significant associations in all quintiles with median intake of about 0.01 g/d or higher).162

The same two studies evaluated DHA intake (Figure 9, plots #22 & 23). NIPPON DATA found no significant association between higher DHA intake and lower CVD death risk (P=0.099).175 The Shanghai Women’s and Men’s Health Studies found a significant association between higher EPA intake and lower risk of CVD death, as with EPA.162 Significant or near-significant (P<0.10) associations were seen in quantiles with median doses of about 1.25 percent Kcal or about 0.02 g/d, or higher.

Six studies evaluated EPA+DHA intake (3 studies; NIPPON DATA80, Shanghai Women’s and Men’s Health Studies, Singapore Chinese Health Study, Takayama, VITAL)72, 162, 170, 175, 176 or EPA+DHA+DPA intake (MRFIT) (Figure 9, plots #26 & 27).47 The Shanghai Women’s and Men’s Health Studies and MRFIT found significant associations between higher marine oil intake and lower CVD death risk.47, 162 The Singapore Chinese Health Study found no significant association between higher marine oil intake and lower CVD death risk in CVD adults, but found a significant association in healthy adults (P=0.002).170 VITAL found no significant associations between higher marine oil intake and lower CVD death risk in both healthy and CVD adults.176 In MRFIT, the association was statistically significant when marine oil intake (either g/d or % Kcal) was analyzed as a continuous variable in a linear model and near-significant (P<0.10) when analyzed across quintiles.47 Both NIPPON DATA80 and Takayama found no significant associations overall.72, 175 For percent Kcal analyses, near-significant associations were found in quantiles with median intake of about 0.30 percent Kcal or higher. In two of the g/d analyses, near-significant associations were found in quantiles with median marine oil intake of about 0.7 g/d.

By meta-analysis (Table 7), overall there is a statistically significant association between marine oil intake and CVD death across a median dose range of 0.066 to 1.58 g/d (effect size per g/d = 0.88; 95% CI 0.82 to 0.95). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.2 g/d) consistently found a stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot closer to 1). This implies the possibility of a ceiling effect (where intake above a certain level adds no further benefit). However, at no dose threshold was there a statistically significant difference between the ES below the dose threshold (knot) and above the threshold. The best fit curve was found with a knot at 0.3 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at 0.2 g/d (P=0.26).

Table 7 Meta-analysis results of observational studies of marine oil (EPA+DHA±DPA) intake and CVD death (including stroke)

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
90,778 | 0.066–1.58 | NA | 0.88 (0.82, 0.95) | | | | | 5
| | 0.1 | | 0.36 (0.07, 1.78) | 0.92 (0.78, 1.09) | 0.28 | 27.0 | 5
| | 0.2 | | 0.54 (0.24, 1.22) | 0.93 (0.78, 1.11) | 0.26 | 23.6 | 5
| | 0.3 | | 0.64 (0.37, 1.10) | 0.93 (0.77, 1.13) | 0.27 | 23.5 | 5
| | 0.4 | | 0.70 (0.46, 1.05) | 0.93 (0.77, 1.14) | 0.31 | 27.9 | 3
| | 0.5 | | 0.72 (0.50, 1.03) | 0.94 (0.76, 1.17) | 0.31 | 27.0 | 3
| | 0.6 | | 0.74 (0.53, 1.01) | 0.95 (0.74, 1.21) | 0.33 | 26.9 | 3
| | 0.7 | | 0.75 (0.56, 1.01) | 0.96 (0.72, 1.28) | 0.37 | 27.5 | 3
| | 0.8 | | 0.78 (0.59, 1.02) | 0.96 (0.69, 1.33) | 0.45 | 28.1 | 3
| | 0.9 | | 0.79 (0.62, 1.02) | 0.97 (0.66, 1.43) | 0.52 | 29.5 | 3
| | 1.0 | | 0.81 (0.64, 1.03) | 0.96 (0.59, 1.56) | 0.62 | 31.8 | 3
| | 1.1 | | 0.83 (0.67, 1.03) | 0.96 (0.50, 1.82) | 0.72 | 35.7 | 3
| | 1.2 | | 0.83 (0.68, 1.02) | 0.96 (0.33, 2.73) | 0.82 | 44.0 | 3

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, ES = effect size, NA = not applicable.

#### n-3 FA Biomarkers

The Cardiovascular Health Study and ULSAM evaluated n-3 FA plasma levels.95, 148

The Cardiovascular Health Study found a significant association between higher total n-3 FA plasma levels and lower risk of CVD death (Figure 9, plot #33).148

Both the Cardiovascular Health Study and ULSAM found no association between plasma ALA levels and CVD death risk (Figure 9, plot # 21).95, 148

For both plasma EPA and DHA levels (separately), the Cardiovascular Health Study found significant associations between higher plasma levels and lower risk of CVD death at 16 years of followup.148 In contrast, ULSAM found no significant association at about 31 years of followup (Figure 9, plots #24 & 30).95

The Cardiovascular Health Study also found a significant association between higher plasma DPA levels and lower risk of CVD death (Figure 9, plot #25).

#### Observational Study Subgroup Analyses

Only the Cardiovascular Health Study reported subgroup analyses.148 In their analysis of ALA intake, they reported no significant difference (without details) in association between participants with high, low, or no fish consumption and between men and women.

## Cardiac Death

### Randomized Controlled Trials

Five RCTs reported on cardiac death (combined CHD and other cardiac death) (Table 8).70, 74, 81, 82, 87 The trials were conducted in a total of 15,596 people with CVD including MI, arrhythmia, and CHD. Only one trial reported cardiac death to be a primary outcome (Marchioli 2002).70

Table 8 Cardiac mortality: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Brouwer 2006 16772624 N. Europe | CVD | EPA+DHA | 0.96 g n-3 FA (0.464 g EPA, 0.335 g DHA) (Marine oil) [E:D]=1.4 | Placebo | 0 (high-oleic acid sunflower oil) | 1 y | Generally good (76% reported taking 80% pills) based on pill counts and confirmed by biomarkers. | 6/273, 2% | 13/273, 5% | OR 0.45 (0.17, 1.20) | 0.111
Leaf 2005 16267249 U.S. | CVD | EPA+DHA | EPA plus DHA of 2.6 g (Marine oil) | Placebo | 0 (Olive oil) | 12 mo | Pill counts and analysis of the phospholipids of red blood cells for their content of EPA and DHA | 9/200, 4.5% | 9/202, 4.5% | OR 1.01 (0.39, 2.60) | 0.983
Marchioli 2002 11997274 Italy | CVD | EPA+DHA | EPA and DHA 0.850–0.882 g/d) (Marine oil) | No intervention | nd | 3.5 y | Followup (adherence was 72.5% at the end of study) | 247/5666, 4.4% | 306/5668, 5.4% | RR 0.65 (0.51, 0.82) | <0.001
Burr 2007 17343767 UK | CVD | Fish advice | EPA 0.45 g/d (diet)^a^ | No fish advice | EPA 0.11 (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 121/1109, 10.9% | 139/1543, 9.0% | Adj HR 1.20 (0.93, 1.53) | 0.16
| CVD | EPA+DHA (advice to take fish oil) | EPA ≤0.51 and DHA ≤0.345 (marine oil)^a^ | No fish advice | EPA 0.11 (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 59/462, 12.8% | 139/1543, 9.0% | Adj HR 1.45 (1.05, 1.99) | 0.024
| CVD | EPA+DHA (advice to take fish oil) | EPA ≤0.51 and DHA ≤0.345 (marine oil)^a^ | Fish advice | EPA 0.45 g/d (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 59/462, 12.8% | 121/1109, 10.9% | OR 1.20 (0.86, 1.67) | nd
Raitt 2005 15956633 U.S. | CVD | EPA+DHA | EPA 0.756 g/d, DHA 0.54 g/d (fish oil) [E:D 1.4] | Placebo | 0 (olive oil: 73% oleic acid, 12% ) | 2 y | RBC and plasma n-3 FA levels | 2/100, 2.0% | 5/100, 5.0% | OR 0.39 (0.07, 2.05) | 0.44

Abbreviations: Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n3 FA = omega-3 fatty acids, n6 = omega-6, OR = odds ratio, PMID = PubMed Identification number, RBC = red blood cell, RCT = randomized controlled trial, RR = relative risk.

#### Marine Oil Versus Placebo

##### CVD Population

Among people with CVD, four compared marine oil (EPA+DHA) to placebo (oleic acid or olive oil) or no intervention in a total of 12,282 participants with arrhythmia, ventricular tachycardia or fibrillation, MI, or CHD,70, 81, 82, 87 and one compared two levels of “fish advice” (dietician to advise to increase fish and/or fish oil supplement intake) with no fish advice in a total of 3114 men with MI or angina.74

Among the four RCTs that compared marine oil (EPA+DHA) to placebo (oleic acid or olive oil) or no intervention EPA+DHA ranged from 0.8 to 2.6 g/d. In the two RCTs reporting sufficient details, the EPA to DHA ratio was 1.4. Compliance was generally good (>70%). The duration of follow-up ranged from 1 to 3.5 years. Three of the four RCTs found that EPA+DHA supplementation did not have significant effects on cardiac death (OR=0.39, 0.45, and 1.01).82, 87 The third RCT found that EPA+DHA supplementation had protective effects against cardiac death (RR 0.65; 95% CI 0.51 to 0.82).70

In the study that compared “fish advice” (advise to increase fish intake in one subgroup and additional advise to take fish oil supplement in a second subgroup) with “no fish advice”,74 the mean EPA intake estimated by the dietary assessment was 0.45 and ≤0.85 g/d in the “fish advice” groups, and was 0.11 in the “no fish advice” group. No estimates for DHA intake levels were reported. Compliance was good (fish intake was significantly increased in the “fish advice” groups) based on the dietary assessments. The trial found that, after 9 years of followup, overall, there was a significant increase in cardiac death between 1571 men with angina who were advised to increase fish intake and 1543 men with angina who were not (adjusted HR 1.26; 95% CI 1.00 to 1.58; P=0.047). The effect was similar but nonsignificant in the subgroup of 1109 men given advice only about increasing fish intake (adjusted HR 1.20, 95% CI 0.93 to 1.53) but larger and statistically significant in 462 men who were advised to take a fish oil supplement (adjusted HR 1.45; 95% CI 1.05 to 1.99).74

#### RCT Subgroup Analyses

The RCT that found a significant increased risk of cardiac death with combined fish diet and EPA+DHA supplements reported subgroup analyses for cardiac death.74 It found nonsignificant interactions between fish advice and the following five pairs of subgroups, based on whether they take nitrates, digoxin, lipid-lowering drugs, anticoagulants, or diuretics.

### Observational Studies

Two studies evaluated a composite outcome of fatal CHD and SCD, both in healthy adult males (Appendix F, Cardiac death section; Figure 10).54, 155 The Health Professionals Follow-up Study found no association between EPA+DHA intake and cardiac death (Figure 10, plot #34). The Physician’s Health Study found no associations between erythrocyte ALA, EPA, DHA, DPA, SDA, or EPA+DHA+DPA levels and cardiac death.50, 155

Figure 10 n-3 FA associations with cardiac death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for cardiac death. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted.

White squares = healthy males.

Abbreviations: DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure demonstrates study or cohort level association between omega-3 fatty acid exposure and hazard ratio. It represents two studies that evaluated a composite outcome of fatal coronary heart disease and sudden death and found no association.

## Coronary Heart Disease Death

### Randomized Controlled Trials

Four RCTs evaluated CHD death (Table 9).48, 51, 90, 119 Of these, one study was conducted in 18,645 participants with dyslipidemia (19.5% with CHD),90 and three were conducted in a total of 6929 people with CVD including MI, arrhythmia, and CHD. Only one trial reported death to be a primary outcome (Yokoyama 2007).90

Table 9 CHD Mortality: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Yokoyama 2007 17398308 Japan | At risk (dyslipidemia; 19.5% with CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 29/9326, 0.3% | 31/9319, 0.3% | HR 0.94 (0.57, 1.56) | 0.812
| At risk | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 11/7503 0.1% | 10/7478 0.1% | HR 1.1 (0.47, 2.6) | 0.822
Sacks 1995 7759696 U.S. | CVD | EPA+DHA+DPA | 6 g/d (suppl) [E:D 1.5] | Placebo | 0 (Olive oil) | 2.4 y | Pill counting (80% for EPA+DHA; 90% for placebo) | 0/31, 0.0% | 1/28, 3.6% | RD −3.6% (−10.4%, 3%) | 0.309
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA (±ALA) | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±ALA) | 0; 2 g/d ALA (Placebo margarine = oleic acid; Plant oil) | 40 mo | 90% of the patients adhered fully to the protocol; verified by biomarkers | 67/2404, 2.8% | 71/2433, 2.9% | HR 0.95 (0.68,1.32) | 0.75
Burr 1989 2571009 UK | CVD | Fish advice, either alone or in combination with fiber advice, fat advice, or both fiber and fat advice. | EPA 0.34 g/d (diet) | No fish advice (Fat advice, fiber advice, fiber and fat advice, or no advice) | EPA 0.09 g/d (diet) | Overall years (10+ y) | Compliance was good based on dietary assessments | 354/1015, 34.9% | 384/1018, 37.7% | Adj HR 0.92 (0.80, 1.07) | NS
Yokoyama 2007 17398308^*^ Japan | CVD (previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 18/1823 1.0% | 21/1841 1.1% | HR 0.87 (0.46, 1.64) | 0.667
| CVD (PAD at any time) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 3/117 2.6% | 7/106 6.6% | HR 0.48 (0.10, 1.98) | 0.308
ALA vs. Placebo
Kromhout 2010 20929341 Netherlands | CVD | ALA (±EPA+DHA) | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±EPA+DHA) | 0; 0.4 g/d EPA−DHA (placebo = oleic acid; Marine oil) [E:D 3:2] | 40 mo | 90% of the patients adhered fully to the protocol; verified by biomarkers | 66/2409, 2.7% | 72/2428, 3.0% | HR 0.92 (0.66, 1.29) | 0.64

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CHD = coronary heart disease, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, Int = intervention, n/N = number with outcome/number analyzed, n3 FA = omega-3 fatty acids, NS = not significant, PAD = peripheral artery disease, PMID = PubMed Identification number, RCT = randomized controlled trial, RD = risk difference.

#### Marine Oil Versus Placebo

##### At-Risk-for-CVD Population

Among people at risk of CVD, one study compared 1.8 g/d EPA ethyl ester combined with statin with control (statin alone) in 18,645 participants with dyslipidemia (19.5% with CHD).90 Local physicians monitored compliance with dietary advice and medication at every clinic visit but the adherence level was not reported. This study found no significant additive effect of EPA supplementation on risk of CHD death compared with statin alone (HR 0.94; 95% CI 0.57 to 1.56). When only the patients without CHD were analyzed, the study still found no significant additive effect of EPA supplementation on risk of CHD death compared with statin alone (HR 1.1; 95% CI 0.47 to 2.6).

##### CVD Population

The same study analyzed the small subgroups of patients with CVD separately. Among people with previous CHD, 1.8 g/d EPA ethyl ester combined with statin was compared with statin alone in 3,664 patients. No significant additive effect of EPA supplementation on risk of CHD death was found (HR 0.87; 95% CI 0.46 to 1.64). Among 223 people with peripheral artery disease, no significant additive effect of EPA supplementation on risk of CHD death compared with statin alone was found (HR 0.48; 95% CI 0.10 to 1.98).90

Among people with CVD, two studies compared marine oil (EPA+DHA) to placebo (oleic acid or olive oil) in a total of 4896 participants with arrhythmia, MI, or CHD,51, 119 one was the 2-by–2 factorial RCT described under Major Adverse Cardiovascular Events.119

A relatively small trial (with 59 participants) compared 6 g/d marine oil (2.88 g/d EPA, 1.92 g/d DHA, 1.2 g/d DPA) to olive oil placebo for 2.4 years, with 80 percent compliance in the marine oil supplement arm (and 90% compliance in the olive oil placebo arm).51 The 2-by–2 factorial trial compared 0.4 g/d of EPA+DHA in margarine to placebo margarine for 40 months with 90 percent compliance, overall.119 Both trials found no significant association between marine oil intake and CHD death, but the smaller trial had only one such death during its followup.

In one trial that compared “fish advice” (advise to increase fish intake) with “no fish advice” in 2033 adults,48 the mean EPA intake estimated by the dietary assessment was 0.34 g/d in the “fish advice” group and 0.09 in the “no fish advice” group. No estimates for DHA intake levels were reported. Compliance was good based on the dietary assessments. No significant difference in risk of CHD death was found (adjusted HR = 0.92; 95% CI 0.66 to 1.29).

#### ALA Versus Placebo

##### CVD Population

The 2-by–2 factorial study compared 2 g/d ALA in margarine to control margarine.119 The trial found no difference in risk of CHD death after 40 months (HR 0.92; 95% CI 0.66 to 1.29).

#### RCT Subgroup Analyses

Two RCTs reported subgroup analysis for CHD death (Table 10). The 2-by–2 factorial study found significant protective effect of EPA+DHA in subjects with diabetes (HR=0.51, P=0.04) that was not seen in subjects without diabetes (HR=1.21, P=0.32); no analysis of a statistical interaction was reported.119 In both subgroups, the effect of ALA on CHD death was nonsignificant (HR=0.87, P=0.63 with diabetes; HR=0.97, P=0.87 without diabetes).

Table 10 CHD mortality: Subgroup analyses, randomized trials

Study Year PMID Region | Population | Subgroups | n-3 FA | Comparator | N Total | P difference | Difference | Favors
Kromhout 2010 20929341 Netherlands | CVD | Diabetes vs. no diabetes | EPA+DHA | Placebo or ALA | 4837 | 0.04 diabetes, 0.34 no diabetes | 0.51 vs. 1.21 | Diabetes (possibly)
| CVD | Diabetes vs. no diabetes | ALA | Placebo or EPA+DHA | 4837 | NS both subgroups
Yokoyama 2007 17398308 Japan | At risk (dyslipidemia; 19.5% with CHD) | No history of CHD vs. history of CHD | EPA + Statin | Statin | 18645 | NS both subgroups

Abbreviations: ALA = alphalinolenic acid, CHD = coronary heart disease, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, n-3 FA = omega-3 fatty acids, NS = not significant, PMID = PubMed Identification number.

In the trial of participants with dyslipidemia (19.5% of whom had CHD),90 no significant effect of EPA was found. In participants with no history of CHD (primary prevention), HR=1.00 (95% CI 0.32 to 3.11). In participants with a history of CHD (secondary prevention), HR=0.64 (95% CI 0.21 to 1.94).

### Observational Studies

Ten studies evaluated associations between n-3 FA intake and biomarkers and CHD death, including the Pooling Project, which pooled data from eight large cohorts (ARIC, FMC, IWHS, NHS, VIP, WHS, ATBC, HPFS) (Appendix F, Death from coronary heart disease section; Figure 11).47, 57, 69, 84, 98, 113, 159, 162, 175, 181, 186 The studies were all conducted in healthy adults with average followup ranging from about 6 to 24 years (median 11.3 years).

Figure 11 n-3 FA associations with CHD death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. Where 95% confidence intervals (vertical lines) are missing, these were not reported in the studies. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females.

Abbreviations: ALA = alphalinolenic acid, CHD = coronary heart disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure demonstrates in 15 different plots coronary the estimate hazard ratio of heart disease death and associations or interactions with exposure to omega-3 fatty acids in observational studies. Ten studies evaluated associations between omega-3 fatty acid intake and biomarkers and coronary heart disease death, Four studies evaluated ALA intake, Two studies found no associations with EPA or DHA intake, Seven studies analyzed EPA+DHA) or EPA+DHA+DPA. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

Eleven studies analyzed n-3 FA intake (Alpha-Tocopherol Beta-Carotene Cancer Prevention, Cardiovascular Health Study, JACC, Japan Public Health Center-Based Study - Cohort I, MORGEN, MRFIT, NIPPON DATA80, Nurses’ Health Study, Pooling Project of Cohort Studies on Diet and Coronary Disease, Shanghai Women’s and Men’s Health Studies, Singapore Chinese Health Study).

The NIPPON DATA80, JACC studies found no associations between total n-3 FA intake (combined) and CHD death after 13 and 24 years of followup (Figure 11, plots #47 & 48).98, 175 The Singapore Chinese Health Study found significant associations between total n-3 FA intake and CHD death after five years of followup (P=0.04).170

Five studies, including the Pooling Project and thus comprising eight study cohorts, evaluated ALA intake (Alpha-Tocopherol Beta-Carotene Cancer Prevention, Cardiovascular Health Study, MRFIT, Pooling Project of Cohort Studies on Diet and Coronary Disease) (Figure 11, plots #35 & 36).47, 57, 159, 170, 181 The Singapore Chinese Health Study found significant associations between total ALA intake and CHD death after five years of followup (P=0.001).170 MRFIT found a statistically significant association between higher ALA intake measured as percent Kcal (energy) in men after about 10 years of followup (with possibly significant associations bound in quartiles with median values above about 0.5% Kcal), but no association with ALA intake measured as g/d.47 The other three studies also found no association (in men, women, or all healthy adults) at 6, 12, and 4–10 years of followup.

By meta-analysis (Table 11), overall there is no statistically significant association between ALA intake and CHD death across a median dose range of 0.59 to 2.5 g/d (effect size per g/d = 0.94; 95% CI 0.85 to 1.03). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.6 to 1.2 g/d) consistently found a stronger association (of higher dose being associated with lower risk) at higher doses than at lower doses (ES above knot < ES below knot); although the differences were generally small and all were nonsignificant. The best fit curve was found with a knot at 0.9 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at 1.2 g/d (P=0.44), the highest dose threshold that could be tested.

Table 11 Meta-analysis results of observational studies of ALA intake and CHD death

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
84,811 | 0.59–2.5 | NA | 0.94 (0.85, 1.03) | | | | | 3
| | 0.6 | | 1.01 (0.78, 1.30) | 0.83 (0.57, 1.21) | 0.53 | 10.8 | 3
| | 0.7 | | 0.98 (0.82, 1.17) | 0.83 (0.57, 1.21) | 0.53 | 10.2 | 3
| | 0.8 | | 0.96 (0.84, 1.09) | 0.83 (0.57, 1.21) | 0.53 | 9.7 | 3
| | 0.9 | | 0.95 (0.85, 1.05) | 0.83 (0.56, 1.24) | 0.56 | 9.3 | 3
| | 1.0 | | 0.94 (0.86, 1.04) | 0.80 (0.49, 1.31) | 0.54 | 9.4 | 3
| | 1.1 | | 0.94 (0.86, 1.03) | 0.72 (0.34, 1.54) | 0.50 | 10.6 | 3
| | 1.2 | | 0.94 (0.87, 1.03) | 0.42 (0.06, 3.20) | 0.44 | 14.5 | 3

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), ALA = alphalinolenic acid, CHD = coronary heart disease, ES = effect size, NA = not applicable.

Two studies (NIPPON DATA80, Shanghai Women’s and Men’s Health Studies) found no associations with EPA or DHA intake (separately) and CHD death at 24 years in one study and at about 6 years in men and 11 years in women in the other study (Figure 11, plots #38, 39, 44 & 45).162, 175

Eight studies analyzed EPA+DHA (5 studies; Japan Public Health Center-Based Study - Cohort I, NIPPON DATA80, Nurses’ Health Study, MORGEN, Shanghai Women’s and Men’s Health Studies Singapore Chinese Health Study69, 84, 143, 162, 170, 175) or EPA+DHA+DPA (2 studies; Alpha-Tocopherol Beta-Carotene Cancer Prevention, MRFIT47, 57) between 6 and 24 years of followup.47 The studies found heterogeneous results (Figure 11, plots #42 & 43). Four studies (MORGEN, MRFIT, Nurses’ Health Study, Singapore Chinese Health Study) found significant associations between higher EPA+DHA±DPA and lower risk of CHD death (with significant associations occurring in quantiles with median intake of at least about 0.1% Kcal or 0.25 g/d).47, 69, 143, 170 One study found an about 80 percent increase in risk of CHD death with higher EPA+DHA intake, but this was not statistically significant (Japan Public Health Center-Based Study - Cohort I, highest vs. lowest quintiles HR=1.79; 95% CI 0.82 to 3.87; P=0.10 across quintiles).84 The remaining three studies found no associations between EPA+DHA±DPA and CHD death risk. Meta-analysis could not be run because intake was inconsistently measured as either g/d or percent Kcal.

By meta-analysis (Table 12), overall there no significant association between marine oil intake and CHD death across a median dose range of 0.04 to 2.1 g/d (effect size per g/d = 1.09; 95% CI 0.76 to 1.57). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.2 g/d) found stronger associations (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot closer to 1) for knots below 0.7 g/d, but stronger associations at higher doses above 0.7 g/d. However, the differences in effect size between lower and higher doses were always highly nonsignificant, implying no difference in association. The best fit curve was found with a knot at 0.5 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at the lowest tested threshold, 0.1 g/d (P=0.46).

Table 12 Meta-analysis results of observational studies of marine oil (EPA+DHA±DPA) intake and CHD death

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
145,148 | 0.04–2.1 | NA | 1.09 (0.76, 1.57) | | | | | 4
| | 0.10 | NA | 0.38 (0.02, 6.25) | 1.31 (0.78, 2.20) | 0.46 | 31.1 | 4
| | 0.20 | NA | 0.66 (0.17, 2.61) | 1.35 (0.73, 2.49) | 0.47 | 29.8 | 4
| | 0.30 | NA | 0.88 (0.42, 1.87) | 1.28 (0.71, 2.34) | 0.57 | 30.2 | 3
| | 0.40 | NA | 1.03 (0.72, 1.48) | 1.20 (0.73, 1.98) | 0.70 | 29.6 | 3
| | 0.50 | NA | 1.06 (0.84, 1.35) | 1.19 (0.71, 2.00) | 0.74 | 29.1 | 3
| | 0.60 | NA | 1.06 (0.87, 1.29) | 1.23 (0.66, 2.27) | 0.69 | 30.1 | 3
| | 0.70 | NA | 1.07 (0.89, 1.28) | 1.25 (0.55, 2.82) | 0.73 | 32.9 | 3
| | 0.80 | NA | 1.10 (0.92, 1.33) | 1.06 (0.56, 2.02) | 0.90 | 97.2 | 3
| | 0.90 | NA | 1.10 (0.90, 1.35) | 1.02 (0.52, 2.00) | 0.82 | 36.2 | 2
| | 1.00 | NA | 1.10 (0.90, 1.35) | 0.98 (0.45, 2.16) | 0.77 | 37.0 | 2
| | 1.10 | NA | 1.10 (0.89, 1.36) | 0.89 (0.31, 2.55) | 0.68 | 38.7 | 2
| | 1.20 | NA | 1.10 (0.89, 1.37) | 0.57 (0.06, 5.22) | 0.55 | 44.2 | 2

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), ALA = alphalinolenic acid, CHD = coronary heart disease, ES = effect size, NA = not applicable.

#### n-3 FA Biomarkers

The Cardiovascular Health Study was the only study to evaluate the association between n-3 FA biomarkers and CHD death.159 At 16 years of followup, higher plasma total n-3 FA and higher plasma DHA were each significantly associated with lower risk of CHD death. No associations were found for ALA, EPA, or DPA plasma levels (Figure 11, plots #37, 40, 41, 46, and 49).

#### Observational Study Subgroup Analyses

The Pooling Project analysis of ALA, found a near-significant interaction by sex (P=0.07), suggesting that higher ALA intake may be protective against CHD death in men (HR=0.77; 95% CI 0.58 to 1.01) but not in women (HR=0.88; 95% CI 0.68 to 1.14).181

## Myocardial Infarction Death

### Randomized Controlled Trials

No RCTs evaluated this outcome.

### Observational Studies

Four studies evaluated n-3 FA and MI death in healthy adults (Appendix F, Death from myocardial infarction section; Figure 12).68, 98, 113, 176 The Shanghai study found a significant association between higher total n-3 FA intake and lower risk of MI death at 12 years of followup, with significant associations found in quintiles with median intake above about 0.05 g/d).162 In contrast, JACC found no association between total n-3 FA intake and MI death at about 13 years of followup.98 In a single analysis of EPA+DHA intake, MORGEN found a significant association between higher EPA+DHA intake and lower risk of MI death at about 11 years of followup, with a significant association found in the quartile with intake >0.19 g/d.143 The VITAL study found no association between higher EPA+DHA intake in CVD adults, but did find a significant association in healthy adults (P=0.029).176

Figure 12 n-3 FA associations with myocardial infarction death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for myocardial infarction death. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults.

Abbreviations: DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure demonstrates in two plots four observational studies that evaluated the association between exposure to omega-3 fatty acid and myocardial infarction death in healthy adults. Two studies found there to be significant associations and one study found no association between total omega-2 fatty acid intake and lower risk of myocardial infarction death at a 13 year followup.

#### Observational Study Subgroup Analyses

The Shanghai study reported no difference in association (with total n-3 FA intake) by baseline total cholesterol to HDL-c ratio.162

## Congestive Heart Failure Death

### Randomized Controlled Trials

#### Marine Oil Versus Placebo

##### At-Risk-for-CVD Population

One trial in 12,505 participants at risk for CVD based on multiple risk factors compared a marine oil supplement with at least 0.85 g/d EPA+DHA with olive oil placebo (Table 13).160 The EPA to DHA ratio ranged from 0.9 to 1.5. Compliance data were not reported. After 5 years of followup, no effect on congestive heart failure (CHF) death was seen (HR=1.00; 95% CI 0.53 to 1.88). CHF death was reported to be a secondary outcome.

Table 13 Congestive heart failure death: RCTs

Study Year PMID Region | Population | Int (n-3 FA) | Int n-3 Dose (Source) [E:D; n-6:3] | Control | Ctrl n-3 Dose (Source) [E:D; n-6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | ≥0.85 g/d (suppl) [E:D 0.9–1.5] | Placebo | 0 (Olive oil) | 5 y | Self-reported (nd on level of adherence) | 19/6239, 0.3% | 19/6266, 0.3% | HR 1.00 (0.53, 1.88) | 0.99

Abbreviations: Ctrl = control, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, Int = intervention, n/N = number with outcome/number analyzed, HR = hazard ratio, n-3 FA = omega-3 fatty acids, n6:3 = omega-6 to omega-3 fatty acid ratio, PMID = PubMed Identification number, RCT = randomized controlled trial.

### Observational Studies

Only JACC evaluated n-3 FA and CHF death (Appendix F, Death from congestive heart failure section; Figure 13).98 In healthy adults, the study found a significant association between higher total n-3 FA intake (combined) and lower risk of CHF death after about 13 years of followup, with significant associations found in quintiles with intake >2.1 g/d.

Figure 13 n-3 FA associations with heart failure death: Observational studies

Study (or cohort) level associations between omega-3 fatty acid (n-3 FA) exposure and hazard ratio (HR) for heart failure death. P values are the study-reported P value for the trend across quantiles.

White triangles = healthy adults.

Abbreviations: n-3 FA = omega-3 fatty acids, HR = hazard ratio

This figure demonstrates the signification association between higher intake and lower heart failure mortality rate. This depicts in one plot the one study that examined omega-3 fatty acid and heart failure death.

## Stroke Death, Total (Ischemic and Hemorrhagic)

### Randomized Controlled Trials

Three RCTs evaluated total stroke death (Table 14).48, 96, 160 One trial was in 12,505 participants at risk for CVD based on multiple risk factors,160 and the other two were in a total of 9008 participants with a history of MI,48 or heart failure.96 No trial reported stroke death as a primary outcome.

Table 14 Total stroke death: RCTs

Study Year PMID Region | Population | Int (n-3 FA) | Int n-3 Dose (Source) [E:D; n-6:3] | Control | Ctrl n-3 Dose (Source) [E:D; n-6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs Placebo
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | ≥0.85 g/d (marine oil) [E:D 0.9:1–1.5:1] | Placebo | 0 (Olive oil) | 5 y | Self-reported (nd on level of adherence) | 19/6239, 0.3% | 18/6266, 0.3% | HR 1.05 (0.55, 2.00) | 0.88
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 1:1.2] | Placebo | 0 (nd) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 50/3494, 1.4% | 44/3481, 1.3% | OR 1.13 (0.75, 1.71)
Burr 1989 2571009 UK | CVD | Fish advice, either alone or in combination with fiber advice, fat advice, or both fiber and fat advice. | EPA 0.34 g/d (diet) | No fish advice (Fat advice, fiber advice, fiber and fat advice, or no advice) | EPA 0.09 g/d (diet) | >10 y | Compliance was good based on dietary assessments | 29/1015, 2.9% | 23/1018, 2.3% | OR 1.23 (0.71, 2.14) | NS

Abbreviations: Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n-3 FA = omega-3 fatty acids, n6:3 = omega-6 to omega-3 fatty acid ratio, NS = not significant, OR = odds ratio, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### Marine Oil Versus Placebo

##### At-Risk-for-CVD Population

One RCT evaluated the effect of marine oil (EPA+DHA) on stroke death compared with placebo (olive oil) in a total of 12,505 participants with high risk for CVD.160 The dose of EPA+DHA was at least 0.85 g/d (composition of the marine oil was not reported). Adherence was verified by participants’ self-report but the level of adherence was not reported. After 5 years, the study found no significant difference in stoke death comparing EPA+DHA with placebo (HR 1.05, 95% CI 0.55 to 2.00).160

##### CVD Population

One trial compared marine oil (EPA+DHA) ethyl ester supplementation (0.85–0.88 g/d) to placebo in 6975 participants with heart failure.96 After 3.9 years of followup, about 30 percent of participants in both study arms were not taking the supplement. No difference was found in risk of stroke death (OR = 1.13; 95% CI 0.75 to 1.71). A second trial compared fish advice (resulting in an average of 0.34 g/d EPA intake) with no fish advice (0.09 g/d EPA intake) in 2033 adults with a history of MI.48 Compliance was not reported. After more than 10 years of followup, no significant difference in stroke death was found (OR=1.23; 95% CI 0.71 to 2.14).

### Observational Studies

Five studies evaluated n-3 FA intake and biomarkers and risk of total stroke death at 5, 12 to 24 years of followup in healthy adults (Appendix F, Death from stroke section; Figure 14).68, 98, 159, 170, 175

Figure 14 n-3 FA associations with total stroke death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults.

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure demonstrates in 11 different plots how total stroke death and associations or interactions with exposure to omega-3 fatty acids in observational studies. Four studies evaluated to omega-3 fatty acid intake and biomarkers and risk of (all cause) stroke death, Three studies evaluated to omega-3 fatty acid intake and EPA, DHA, and EPA+DHA intake and risk of stroke death, one study evaluated to omega-3 fatty acids biomarkers. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

Four studies evaluated n-3 FA intake and risk of stroke death (JACC, NIPPON DATA80, Shanghai, Singapore Chinese Health Study).68, 98, 170, 175 All analyses were nonsignificant, including for total n-3 FA (combined) intake (all four studies) at 5, 12, 13, and 24 years of followup (Figure 14, plots #61 & 62); and EPA, DHA, and EPA+DHA intake (separately) in the NIPPON DATA80 study at 24 years of followup (Figure 14, plots #54, 57, & 59).175 The Singapore Chinese Health Study also found no significant associations between higher ALA or EPA+DHA intake (separately) and lower risk of stroke death.170

#### n-3 FA Biomarkers

Only the Cardiovascular Health Study evaluated n-3 FA biomarkers.159 The study found near-significant associations (P<0.10) between higher plasma total n-3 FA (Figure 14, plot #63), DHA (Figure 14, plot #55), and DPA levels (Figure 14, plot #56), separately, and lower risk of stroke death after 16 years of followup (P=0.092, 0.082, and 0.056, respectively). The study found no association with plasma EPA levels (Figure 14, plot #60).

#### Observational Study Subgroup Analyses

The Shanghai study found no significant difference in association (of total n-3 FA intake) by baseline total cholesterol to HDL-c ratio.162

## Ischemic Stroke Death

### Randomized Controlled Trials

No RCTs evaluated this outcome.

### Observational Studies

Two studies evaluated the association between n-3 FA intake and risk of ischemic stroke death in healthy adults (Appendix F, Death from ischemic stroke section; Figure 15).98, 162 Both found significant associations. JACC found an association between higher intake of total n-3 FA (combined) and lower risk of ischemic stroke death after about 13 years of followup (Figure 15, plot #66), with significant associations found in quintiles with median intake of about 2 g/d or more.98 The Shanghai Women’s and Men’s Health Studies found similar significant associations with higher EPA (particularly for median intake >0.07 g/d in men an d>0.06 g/d in women), DHA (particularly for median intake >0.15 g/d), and combined EPA+DHA intake (in separate analyses) with about 11 years of followup in women and 6 years of followup in men (Figure 15, plots #64 & 65; EPA+DHA not plotted because no data were provided for median intake per quantile).162

Figure 15 n-3 FA associations with ischemic stroke death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for ischemic stroke death. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles.

White triangles = healthy adults.

Abbreviations: DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure represents in three plots the three studies that evaluated the association between omega-3 fatty acid intake and risk of ischemic stroke death in healthy adults, associations with higher EPA, DHA, and combined EPA+DHA intake. Two studies found significant associations. And a third found an association between higher intake of total omega-3 fatty acid (combined) and lower risk of ischemic stroke death after about 13 years of followup with significant associations found in quintiles with median intake of about 2 g/d or more. One study found a significant association between higher total n-3 FA intake (combined) and lower risk of CHF death after about 13 years of followup, with significant associations found in quintiles with intake >2.1 g/d. These plots replicate results reported in Appendix F.

#### Observational Study Subgroup Analyses

The Shanghai study found no significant difference in association (of total n-3 FA intake) by baseline total cholesterol to HDL-c ratio.162

## Hemorrhagic Stroke Death

### Randomized Controlled Trials

No RCTs evaluated this outcome.

### Observational Studies

Only the Shanghai Women’s and Men’s Health Studies evaluated hemorrhagic stroke death (Appendix F, Death from hemorrhagic stroke section; Figure 16).162 The study found no association between EPA, DHA, and EPA+DHA intake (not graphed because no data on median intake per quantile), separately, and risk of hemorrhagic stroke death after about 11 years followup in women and 6 years followup in men (combined analyses).

Figure 16 n-3 FA associations with hemorrhagic stroke death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome.

White triangles = healthy adults.

Abbreviations: DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure represents the results of a single observational study that examines the relationship between omega-3 fatty acid intake and hemorrhagic stroke death. EPA, DHA intake are graphed. The study found no association between EPA, DHA, and EPA+DHA intake which was not graphed because no data on median intake per quantile, separately, and risk of hemorrhagic stroke death after 11 years followup in women and 6 years follow up in men.

## Death, All-Cause

### Randomized Controlled Trials

Eighteen RCTs evaluated all-cause death (Table 15).48, 49, 56, 67, 70, 74, 81, 82, 87, 90, 96, 115, 119, 121, 123, 146, 157, 160 Of these, one study was conducted in 12,716 generally healthy participants,49 three were in a total of 13,713 participants at risk of CVD (defined as dyslipidemia,90 hypercholesterolemia,115 or a combination of various risk factors160), and 14 in a total of 50,386 participants with CVD including previous persistent AFib,157 diabetes or a history of CVD,146 arrhythmia,82, 87 CHD,56 ventricular tachycardia or fibrillation,81 all CVD,123 MI,48, 67, 70, 119, 121 heart failure,96 and angina.74 Four of the trials reported all-cause death to be a primary outcome (Burr 2003, Kromhout 2010, Marchioli 2002, Tavazzi 2008).70, 89, 96, 119

Table 15 All-cause mortality: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Einvik 2010 20389249 Norway | At Risk | EPA+DHA+diet intervention | 2.02 g/d (Marine oil) [E:D 1.4] | Placebo+diet intervention | 0 (Corn oil)) | 3 y | >90% of the tablets were taken based on pharmacy records, and verified by biomarkers | 14/282, 4.96% | 24/281, 8.54% | Adj HR 0.53 (0.27, 1.04) | 0.063
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | ≥0.85 g/d (suppl) [E:D 0.9–1.5] | Placebo | 0 (Olive oil) | 5 y | Self-reported (nd on level of adherence) | 348/6239, 5.6% | 337/6266, 5.4% | HR 1.03 (0.88, 1.19) | 0.73
Yokoyama 2007 17398308 Japan | At risk (dyslipidemia) | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 286/9326, 3.1% | 265/9319, 2.8% | HR 1.09 (0.92, 1.28) | 0.333
Macchia 2013 23265344 Argentina and Italy | CVD | EPA+DHA | 0.85–0.882 (suppl) [nd] | Placebo | 0 (Olive oil) | 12 mo | nd | 4/289, 1.4% | 5/297, 1.7% | HR 0.80 (0.21, 3.00) | NS
Bosch 2012 22686415 Canada | CVD | EPA+DHA | 0.84 g/d (Marine oil) [E:D 1.24] | Placebo | 0 (Olive oil) | 6+ y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 951/6281, 15.1% | 964/6255, 15.4% | Adj HR 0.98 (0.89, 1.07) | 0.63
Brouwer 2006 16772624 N Europe | CVD | EPA+DHA | 0.96 g n-3 FA (0.464 g EPA, 0.335 g DHA) (Marine oil) [E:D=1.4] | Placebo | 0 (high-oleic acid sunflower oil) | 1 y | Generally good (76% reported taking 80% pills) based on pill counts and confirmed by biomarkers. | 8/273, 3% | 14/273, 5% | OR 0.56 (0.23, 1.35) | 0.142
Leaf 2005 16267249 U.S. | CVD | EPA+DHA | EPA plus DHA of 2.6 g (Marine oil) | Placebo | 0 (Olive oil) | 12 mo | Pill counts and analysis of the phospholipids of red blood cells for their content of EPA and DHA. Noncompliance ~35% | 13/200, 6.5% | 12/202, 5.9% | OR 1.10 (0.49, 2.47) | 0.816
Galan 2010 21115589 France | CVD | EPA+DHA | EPA 0.4 g/d DHA 0.2 g/d (Marine oil) [E:D=2] | Placebo | 0 (nd) | 4.7 y | Patient reported (86% reported they took >=80% of allocated treatment) | 58/1253, 4.7% | 59/1248, 4.7% | Adj HR 1.03 (0.72, 1.48) | 0.88
Nilsen 2001 2001 11451717 Norway | CVD | EPA+DHA | EPA-DHA 3.4–3.528 g/d (Marine oil) [E:D=0.5] | Placebo | 0 (Corn oil) | median 2.4 y | nd (82% in fish oil group; 86% in the placebo group ) | 21/150, 14% | 18/150, 12% | OR 1.19 (0.61, 2.34) | 0.607
Rauch 2010 21060071 Germany | CVD | EPA+DHA | 0.46 g EPA, 0.38 g DHA (Marine oil) [E:D=1.2] | Placebo | 0 (Olive oil) | 1 y | Pill counts at 3 months and 12 months (≥70% of study period) | 88/1919, 4.6% | 70/1885, 3.7% | OR 1.25 (0.90, 1.72) | 0.18
Raitt 2005 15956633 U.S. | CVD | EPA+DHA | EPA 0.756 g/d, DHA 0.54 g/d (fish oil) [E:D 1.4] | Placebo | 0 (olive oil: 73% oleic acid, 12% ) | 2 y | RBC and plasma n-3 FA levels | 4/100, 4.0% | 10/100, 10.0% | OR 0.38 (0.11, 1.24) | 0.16
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 (nd) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 955/3494, 27.3% | 1014/3481, 29.1% | Adj HR 0.91 (0.833, 0.998) | 0.041
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA (±ALA) | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±ALA) | 0; 2 g/d ALA (Placebo margarine = oleic acid; Plant oil) | 40 mo | 90% of the patients adhered fully to the protocol; verified by biomarkers | 186/2404, 7.7% | 184/2433, 7.6% | HR 1.01 (0.82, 1.24) | 0.92
Eritsland 1996 8540453 Norway | CVD | EPA+DHA | EPA 2.04 g/d, DHA 1.28 g/d (Marine oil) [E:D=1.6] | No intervention | 0 | 1 y | Tablet and capsule accounts (88% were taken), and serum phospholipid FA | 8/317, 2.5% | 6/293, 2.0% | OR 1.24 (0.42, 3.61) | 0.695
| CVD | EPA+DHA + Aspirin | EPA 2.04 g/d, DHA 1.28 g/d (Marine oil) [E:D=1.6] | Aspirin | 0 | 1 y | Tablet and capsule accounts (88% were taken), and serum phospholipid FA | 5/143, 3.5% | 4/148, 2.7% | OR 1.3 (0.34, 4.96) | 0.697
| CVD | EPA+DHA + Warfarin | EPA 2.04 g/d, DHA 1.28 g/d (Marine oil) [E:D=1.6] | Warfarin | 0 | 1 y | Tablet and capsule accounts (88% were taken), and serum phospholipid FA | 3/174, 1.7% | 2/145, 1.4% | OR 1.25 (0.21, 7.61) | 0.805
Marchioli 2002 11997274 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Marine oil) [E:D 0.5] | No intervention | nd | 42 mo | Followup (adherence was 72.5% at the end of study) | 477/5679, 8.4% | 554/5653, 9.8% | RR 0.79 (0.66, 0.93) | 0.0006
Burr 1989 2571009 UK | CVD | Fish advice, either alone or in combination with fiber advice, fat advice, or both fiber and fat advice. | EPA 0.34 g/d (diet) | No fish advice (Fat advice, fiber advice, fiber and fat advice, or no advice) | EPA 0.09 g/d (diet) | Overall years (10+ y) | Compliance was good based on dietary assessments | 530/1015, 52.2% | 553/1018, 54.3% | Adj HR 0.95 (0.85, 1.07) | NS
Burr 2007 17343767 UK | CVD | Fish advice | EPA 0.45 g/d (diet)^a^ | No fish advice | EPA 0.11 (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 198/1109, 11.0% | 242/1543, 15.7% | Adj HR 1.13 (0.94, 1.37) | 0.20
| CVD | EPA+DHA (advice to take fish oil) | EPA ≤0.51 and DHA ≤0.345 (marine oil)^a^ | No fish advice | EPA 0.11 (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 85/462, 18.4% | 242/1543, 15.7% | Adj HR 1.19 (0.92, 1.54) | 0.19
| CVD | EPA+DHA (advice to take fish oil) | EPA ≤0.51 and DHA ≤0.345 (marine oil)^a^ | Fish advice | EPA 0.45 g/d (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 85/462, 18.4% | 198/1109, 11.0% | OR 1.04 (0.78, 1.37) | nd
ALA vs. Placebo
Natvig 1965 5756076 Norway | Healthy | ALA | ALA 5.2 g/d (Linseed oil) | Control oil | ALA 0.13 g/d (Sunflower seed oil) | 1 y | nd | 40/6690, 6% | 43/6716, 6% | OR 0.93 (0.61, 1.44) | 0.755
Kromhout 2010 20929341 Netherlands | CVD | ALA (±EPA+DHA) | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±EPA+DHA) | 0; 0.4 g/d EPA-DHA (placebo = oleic acid; Marine oil) [E:D 3:2] | 40 mo | 90% of the patients adhered fully to the protocol; verified by biomarkers | 182/2404, 7.6% | 188/2433, 7.7% | HR 0.97 (0.79, 1.19) | 0.8

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, NS = not significant, OR = odds ratio, RBC = red blood cell, RCT = randomized controlled trial, RR = relative risk.

#### Marine Oil Versus Placebo

Meta-analysis of the 17 RCTs of marine oil versus placebo yielded a nonsignificant summary effect size for risk of all-cause death: HR=0.97 (95% CI 0.92 to 1.03) (Figure 17).

Figure 17 All-cause death: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, n/N = number with outcome/number analyzed, n-3 FA = omega-3 fatty acids, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure shows that a meta-analysis of the 17 randomized control trials of marine oil versus placebo yielded a non-significant summary effect size for risk of all-cause death. Eight studies compared marine oil (EPA+DHA) with placebo, two compared “fish advice”. The summary hazard ratio was =0.97, (0.92, 1.03); almost identical to the nonsignificant summary hazard ratio for all randomized control trials, regardless of population.

##### At-Risk-for-CVD Population

Three RCTs compared EPA+DHA or EPA alone with placebo in participants at risk of CVD.

Among 13,068 participants, two RCTs compared marine oil (EPA+DHA) with placebo (corn or olive oil) (Figure 17).115, 160 The doses of EPA+DHA were greater than 0.85 and 2.02 g/d, with EPA to DHA ratio ranging from 0.9 to 1.5. Compliance was greater than 90% in one study and was not reported in another. The duration of followup was 3 and 5 years. Both RCTs found that EPA+DHA had no significant effect on all-cause death compared with placebo (adjusted HR 0.53, 95% CI 0.27 to 1.04; HR 1.03, 95% CI 0.88 to 1.19).

One study of 18,645 patients with dyslipidemia compared 1.8 g/d EPA ethyl ester plus statin with statin alone. Compliance was monitored by local physicians but not reported in the study. Followup time was 4.6 years, and no significant additive effect of EPA supplementation on all-cause death was found (HR 1.09; 95% CI 0.92 to 1.28).90

Subgroup meta-analysis (as part of a meta-analysis of all marine oil vs. placebo trials) yielded a summary HR of 1.04 (95% CI 0.93 to 1.16) for people at risk for CVD.

##### CVD Population

Among the 14 RCTs that were conducted in participants with CVD (Figure 17), nine studies compared marine oil (EPA+DHA) with placebo,67, 82, 87, 96, 121, 123, 146, 157 three compared marine oil (EPA+DHA) with no intervention,56, 70, 81 two compared “fish advice” (advise to increase fish intake in both studies with additional advise to take fish oil supplement in later study) with “no fish advice”,48, 74 and one was the 2-by–2 factorial RCT described under Major Adverse Cardiovascular Events that compared EPA+DHA, EPA+DHA and ALA, ALA, and oleic acid margarines.119

Among the 12 studies that compared marine oil (EPA+DHA) with placebo or no intervention, a total of 44,629 participants with CVD were examined.56, 67, 70, 81, 82, 87, 96, 119, 121, 123, 146, 157 The doses of EPA+DHA ranged from 0.4 g/d to 3.32 g/d. Among the nine RCTs reporting sufficient detail, the EPA to DHA ratio ranged from 0.5 to 2. Compliance ranged from 65 to 88 percent. The duration of follow-up ranged from 1 year to more than 6 years. Two of the 12 RCTs found that EPA+DHA had significant effect on reducing all-cause death compared with placebo or no intervention in 6975 participants with heart failure (adjusted HR 0.91; 95% CI 0.833 to 0.998) and in 11,332 participants with MI (RR 0.79; 95% CI 0.66 to 0.93). The other 10 RCTs found that EPA+DHA did not have significant effect on all-cause death with OR/HR ranging from 0.38 to 1.25.

Among the two studies that compared “fish advice” with “no fish advice”,48, 74 a total of 5147 participant with MI or angina were examined. The mean EPA intake estimated by the dietary assessment was 0.34 and 0.45 g/d in the “fish advice” groups, and was 0.09 and 0.11 in the “no fish advice” groups. No estimates for DHA intake levels were reported. Compliance was good (fish intake was significantly increased in the “fish advice” groups) based on the dietary assessments. Both RCTs found no significant difference in the risk of all-cause death between groups (HR 0.95; 95% CI 0.85 to 1.07; HR 1.15, 95% CI 0.92 to 1.32).

Across the 14 RCTs of CVD populations, the summary HR (Figure 17) was 0.96 (95% CI 0.90 to 1.02); almost identical to the nonsignificant summary HR for all RCTs, regardless of population (HR 0.97; 95% CI 0.92 to 1.03).

#### ALA Versus Placebo

##### Healthy Population

Among 12,716 healthy people, one RCT compared ALA oil (linseed oil) to control oil (sunflower seed oil).49 The doses of ALA were 5.2 and 0.13 g/d, respectively. Compliance was not reported. After 1-year followup, there was no significant difference in all-cause death between the two groups (OR 0.93; 95% CI 0.61 to 1.44).

##### CVD Population

Among 4837 participants with MI, the 2-by–2 factorial RCT found no significant difference in the risk of all-cause death compared with the groups received EPA+DHA alone or placebo margarines (HR 0.97; 95% CI 0.79 to 1.19).119

#### RCT Subgroup Analyses

Four RCTs included subgroup analysis for all causes of death (Table 16). All trials compared marine oil against placebo. One trial found no significant difference in effect between patients with and without hypertension (P interaction = 0.67).70 Among the two analyses of diabetes vs no diabetes subgroups neither reported a statistically significant interaction between diabetes and marine oils.70, 96 One study found no interactions between marine oil and age, left ventricular ejection fraction, ischemic cause versus nonischemic cause of existing CVD, New York Heart Association level, total cholesterol, or statin use. A third study found no significant difference in effect regardless of B vitamin supplementation.123 The fourth study found no difference in effect between patients with history of CVD compared to patients without a history of CVD.115

Table 16 All-cause death: Subgroup analyses, randomized trials

Study | Population | Subgroups | n-3 FA | Comparator | N Total | P difference | Difference | Favors
Marchioli 2002 11997274 Italy | CVD | HTN vs no HTN | EPA+DHA | Placebo | 11323 | 0.67
| | Diabetes vs no diabetes | EPA+DHA | Placebo | 11323 | 0.50
Tavazzi 2008 18757090 Italy | CVD | Diabetes vs no diabetes | EPA+DHA | Placebo | 6975 | NS
| | Age <69 vs ≥69 years | EPA+DHA | Placebo | 6975 | NS
| | Left ventricular ejection fraction ≤40% vs >40% | EPA+DHA | Placebo | 6975 | NS
| | Ischemic cause vs nonischemic cause | EPA+DHA | Placebo | 6975 | NS
| | New York Heart Association II vs III or IV | EPA+DHA | Placebo | 6975 | NS
| | Total cholesterol ≤4.87 vs >4.87 mmoL/L | EPA+DHA | Placebo | 6975 | NS
| | Statin vs no statin | EPA+DHA | Placebo | 6975 | NS
Galan 2010 21115589 France | CVD | B vitamin vs no B vitamin | EPA+DHA | Placebo | 2501 | NS
Einvik 2010 20389249 Norway | At Risk | CVD vs no CVD | EPA+DHA | Placebo | 563 | NS

Abbreviations: CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HTN = hypertension, n-3 FA = omega-3 fatty acids, NS = not significant, PMID = PubMed Identification number.

Meta-regression of the marine oil trials found no significant interaction between n-3 FA dose (P=0.54), followup time (P=0.19), or between at risk and CVD populations (P=0.75)

### Observational Studies

Seven studies evaluated the associations between n-3 FA intake or biomarker levels and all-cause death, mostly in healthy adults after 7 to 30 years of followup (Appendix F, All-cause death section; Figure 18); one study evaluated CVD patients with a history of MI after 4 years of followup.47, 72, 95, 98, 148, 154, 159, 162, 186 Most analyses found significant associations between higher n-3 FA intake or biomarker level and reduced risk of death.

Figure 18 n-3 FA associations with all-cause death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. Where 95% confidence intervals (vertical lines) are missing, these were not reported in the studies.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females.

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure presents 12 plots of the hazard ratio association between omega-3 fatty acid intake and all-cause death from longitudinal observational studies. Measures of omega-3 fatty acid represented here include ALA intake, ALA plasma, DHA Intake, DHA plasma, PDA Plasma, EPA+DHA+DPA intake, EPA intake, EPA plasma, total omega-3 fatty acid intake and total omega-3 fatty acid plasma, Five studies evaluated omega-3 fatty acid intake and the risk of death, two studies evaluated ALA intake; three studies found heterogeneous associations between EPA+DHA (or EPA+DHA+DPA) intake and mortality risk; three studies evaluated associations between omega-3 fatty acid biomarkers and risk of death; two studies evaluated ALA biomarkers; three studies evaluated EPA biomarkers and also DHA biomarkers; three observational studies conducted subgroup analyses of the associations between omega-3 fatty acid and all-cause mortality. Most analyses found significant associations between higher omega-3 fatty acid intake or biomarker level and reduced risk of death. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

Six studies evaluated n-3 FA intake and the risk of death (Cardiovascular Health Study, JACC, MRFIT, Shanghai Women’s and Men’s Health Studies [two separate studies analyzed together], Takayama, VITAL).47, 72, 98, 159, 162, 176

JACC found no association between total n-3 FA intake (combined) and all-cause death in healthy adults after about 13 years of followup (Figure 18, plot #79).98

Two studies evaluated ALA intake. MRFIT and the Cardiovascular Health Study both found significant associations between higher ALA intake and reduced death in healthy men after about 10 years and healthy adults ≥65 years old after 12 years (Figure 18, plots # 69 & 70), with significant or larger associations found in median quantiles with intakes above about 1.6 g/d, 1 percent Kcal, or 2.4 percent of fat intake.47, 159

In a combined analysis (of women and men), the Shanghai Women’s and Men’s Health Studies found a significant associations between higher EPA and DHA intakes (separately) and reduced death after about 11 years of followup in the women and 6 years of followup in the men (Figure 18, plots #72 & 77), with significant associations found for quintiles with median intakes above 0.01 g/d of EPA and above 0.02 g/d of DHA.162

Four studies found heterogeneous associations between EPA+DHA (or EPA+DHA+DPA) intake and death risk (Figure 18, plots #75 & 76). MRFIT found near-significant associations between higher marine oil intake and death after 10 years of followup (P<0.10).47 The Takayama study found no association in healthy men, but significantly lower death among women with higher marine oil intake after 7 years of followup.72 The combined Shanghai Women’s and Men’s Health Studies found a significant association between higher marine oil intake and lower risk of death in women after 11 years of followup and men after 6 years of followup.162 The VITAL study found a significant association between higher marine intake and lower risk of death in healthy adults after 6 years of followup (P=0.004).176 Across studies, associations were large or near-significant (P<0.10) in quantiles with median intake above about 0.3 percent Kcal or about 0.7 or 1.2 g/d.

By meta-analysis (Table 17), overall there no significant association between marine oil intake and all-cause death across a median dose range of 0.066 to 1.58 g/d (effect size per g/d = 0.62; 95% CI 0.31 to 1.25). However, meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.2 g/d) consistently found stronger associations (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot closer to 1). This implies the possibility of a ceiling effect (where intake above a certain level adds no further benefit). For thresholds ≤0.4 g/d the associations are statistically significant at lower doses, but not statistically significant at higher doses. The difference between low- and high-dose associations is statistically significantly different at a threshold of 0.2 g/d (P=0.047). The best fit curve was found with a knot at 0.3 g/d. This analysis may suggest that marine oil intake above about 0.2 to 0.4 g/d may not further strengthen any association between higher marine oil intake and lower rate of all-cause death.

Table 17 Meta-analysis results of observational studies of marine oil (EPA+DHA±DPA) intake and all-cause death

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
100,767 | 0.066–1.58 | NA | 0.62 (0.31, 1.25) | | | | | 3
| | 0.1 | | 0.24 (0.07, 0.82) | 0.71 (0.38, 1.34) | 0.10 | 20.4 | 3
| | 0.2 | | 0.36 (0.15, 0.87) | 0.82 (0.52, 1.28) | 0.047 | 17.4 | 3
| | 0.3 | | 0.43 (0.19, 0.98) | 1.09 (0.81, 1.47) | 0.09 | 15.1 | 3
| | 0.4 | | 0.53 (0.28, 0.98) | 1.12 (0.76, 1.65) | 0.12 | 20.5 | 2
| | 0.5 | | 0.55 (0.29, 1.04) | 1.19 (0.69, 2.06) | 0.18 | 20.9 | 2
| | 0.6 | | 0.57 (0.30, 1.08) | 1.25 (0.60, 2.64) | 0.22 | 21.5 | 2
| | 0.7 | | 0.58 (0.30, 1.12) | 1.35 (0.47, 3.87) | 0.28 | 22.4 | 2
| | 0.8 | | 0.60 (0.30, 1.17) | 1.47 (0.29, 7.54) | 0.38 | 23.4 | 2
| | 0.9 | | 0.60 (0.31, 1.18) | 1.54 (0.10, 24.2) | 0.54 | 24.4 | 2
| | 1.0 | | 0.60 (0.31, 1.19) | 1.19 (0.04, 36.2) | 0.71 | 25.6 | 2
| | 1.1 | | 0.60 (0.31, 1.20) | 1.47 (0.01, 188) | 0.73 | 27.5 | 2
| | 1.2 | | 0.60 (0.31, 1.19) | 6.17 (0.00, >999) | 0.73 | 31.6 | 2

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, ES = effect size, HTN = hypertension, n-3 FA = omega-3 fatty acids, NA = not applicable.

The VITAL study found a significant association between higher EPA and DHA intake (separately) and lower risk of death in healthy adults after 6 years of followup (EPA: P=0.014, DHA: P=0.004).176

#### n-3 FA Biomarkers

Three studies evaluated associations between n-3 FA biomarkers and risk of death, two in healthy adults, one in CVD patients with a history of MI.

The Cardiovascular Health Study found a significant association between higher plasma n-3 FA levels (combined) and risk of death in healthy adults ≥65 years after 16 years of followup (Figure 18, plot #80).148

Two studies evaluated ALA biomarkers (Figure 18, plot #71). The Cardiovascular Health Study and ULSAM found no significant associations between plasma ALA and risk of death at 16 and 31 years of followup in healthy adults.95, 148

Three studies evaluated EPA biomarkers (Figure 18, plot #78), one in a CVD population. The Osaka Acute Coronary Insufficiency Study found no association between blood EPA levels and death in patients with a history of MI after 4 years of followup. Similarly, ULSAM found no association with plasma EPA after 31 years of followup.95 In contrast, the Cardiovascular Health Study found a significantly lower risk of death with higher plasma EPA levels after 16 years of followup in healthy adults ≥65 years old.148

The same three studies evaluated DHA biomarkers (Figure 18, plot #73). In contrast with its finding regarding blood EPA levels, the Osaka Acute Coronary Insufficiency Study found a significant association between higher blood DHA levels and reduced death. In ULSAM and the Cardiovascular Health Study, findings were concordant between blood EPA and DHA levels, such that the former found no association with death and the latter found a significant association between higher plasma DHA levels and lower death.95, 148

The Cardiovascular Health Study also found a significant association between higher plasma DPA levels and lower all-cause death in healthy adults (Figure 18, plot #74).

#### Observational Study Subgroup Analyses

Three observational studies conducted subgroup analyses of the associations between n-3 FA and all-cause death (Table 18). The Takayama study implied no difference in association of EPA+DHA intake between men and women.72 The Cardiovascular Health Study found no difference in association of intake of or plasma ALA based on baseline fish consumption.148 The Osaka Acute Coronary Insufficiency Study evaluated 12 sets of subgroups for both blood DHA and blood EPA, as listed in Table 18. A statistically significant interaction was found between blood EPA and hypertension (P interaction = 0.015). In participants with hypertension, no association was found between blood EPA and risk of death (HR=0.96); however, in participants with no hypertension, higher blood EPA was associated with higher risk of dying (HR=8.23). The study also found near-significant interactions between blood EPA and diabetes (P interaction = 0.089, favoring those without diabetes) and statin use (P interaction = 0.062, favoring those not using statins).

Table 18 All-cause death: Subgroup analyses, observational studies

Study | Subgroups | n-3 FA | N Total | P difference | Difference | Favors
Takayama72 | Men vs Women | EPA+DHA intake | 30480 | NS (implied)
Cardiovascular Health Study148 | Fish consumption vs low or no fish consumption | ALA (Plasma or Intake) | 4432 | NS
| Men vs Women | | | NS
Osaka Acute Coronary Insufficiency Study154 | Age <65 vs ≥65 years | DHA (Blood) | 671 | 0.63
| Male vs Female | | | 0.83
| Diabetes vs. no diabetes | | | 0.21
| Hypertension vs. no hypertension | | | 0.30
| Dyslipidemia vs. no dyslipidemia | | | 0.31
| LDL-c <100 vs ≥100 mg/dL | | | 0.80
| HDL-c <40 vs ≥40 mg/dL | | | 0.81
| Tg <150 vs. ≥ 150 mg/dL | | | 0.56
| eGFR <60 vs. ≥60 mL/min | | | 0.69
| Statin vs no statin | | | 0.31
| ACEi/ARB vs. no ACEi/ARB | | | 0.40
| Beta blocker vs. no beta blocker | | | 0.77
| Age <65 vs ≥65 years | EPA (Blood) | 671 | 0.15
| Male vs Female | | | 0.24
| Diabetes vs. no diabetes | | | 0.089 | HR 2.73 vs. 0.92 | No diabetes
| Hypertension vs. no hypertension | | | 0.015 | HR 0.96 vs. 8.23 | Hypertension
| Dyslipidemia vs. no dyslipidemia | | | 0.44
| LDL-c <100 vs ≥100 mg/dL | | | 0.74
| HDL-c <40 vs ≥40 mg/dL | | | 0.94
| Tg <150 vs. ≥ 150 mg/dL | | | 0.56
| eGFR <60 vs. ≥60 mL/min | | | 0.38
| Statin vs no statin | | | 0.062 | HR 2.64 vs. 0.83 | No statin
| ACEi/ARB vs. no ACEi/ARB | | | 0.97
| Beta blocker vs. no beta blocker | | | 0.72

Abbreviations: ARB = angiotensin receptor blocker, ACEi = angiotensin-converting enzyme inhibitor, ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, eGFR = epidermal growth factor receptor, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, HR = hazard ratio, LDL-c = low density lipoprotein cholesterol, n-3 FA = omega-3 fatty acids, NS = not significant, Tg = triglycerides.

## Coronary Heart Disease, Incident

### Randomized Controlled Trials

No RCT evaluated incident CHD.

### Observational Studies

Eleven studies evaluated the associations between intake and biomarkers of n-3 FA and incident CHD (Appendix F, Coronary heart disease section; Figure 19).54, 57, 69, 78, 84, 127, 135, 148, 149, 171, 172, 186. Definitions of CHD outcomes varied across studies, but mostly included both fatal and nonfatal events. All studies were conducted in generally healthy adults. The median followup duration across studies was 11.5 years (range of average followup 6 to 23 years). Studies found a mix of both significant associations between higher n-3 FA intake or biomarker levels and lower risk of CHD or a lack of associations.

Figure 19 n-3 FA associations with incident coronary heart disease: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, black circles = adults with dyslipidemia (at risk), white squares = healthy males, black squares = healthy females.

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, FA = fatty acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure presents in 17 plots the estimate hazard ratio of the association between omega-3 fatty acid intake and biomarkers and incident coronary heart disease from eleven longitudinal observational studies. Measures of Omega-3 fatty acid include: ALA intake, DPA intake and levels, EPA+DHA or EPA+DHA+DPA intake, biomarkers, phospholipid levels, blood or plasma levels of total omega-3 fatty acid combined. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

Ten studies evaluated n-3 FA intake and risk of CHD (Alpha-Tocopherol, Beta-Carotene Cancer Prevention, Cardiovascular Health Study, Glostrup Population Studies, Health Professional Follow-up Study, Japan Public Health Center-Based Study - Cohort I, MESA, MORGEN, Nurses’ Health Study, Pooling Project of Cohort Studies on Diet and Coronary Disease, Spanish EPIC).

Six studies evaluated ALA intake with 6 to 23 years of followup (Pooling Project of Cohort Studies on Diet and Coronary Disease, Alpha-Tocopherol Beta-Carotene Cancer Prevention, Cardiovascular Health Study, Glostrup Population Studies, MESA, MORGEN). One of these studies, the Pooling Project, pooled data from eight large cohorts (ARIC, FMC, IWHS, NHS, VIP, WHS, ATBC, HPFS); thus, overall 13 study cohorts were included (Figure 19, plot #81). Individually, none of the studies found associations between ALA intake and CHD.

By meta-analysis (Table 19), overall there is no association between ALA intake and CHD across a median dosage range of 0.2 to 2.5 g/d (effect size per g/d = 0.97; 95% CI 0.92 to 1.03). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.4 g/d) consistently found marginally smaller ES at lower doses than at higher doses. At no dose threshold was there a statistically significant difference between the ES below the dose threshold (knot) and above the threshold. The best fit curve was found with a knot at 0.7 g/d, the threshold that also had the lowest P value (P=0.34).

Table 19 Meta-analysis results of observational studies of ALA intake and CHD

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
73,093 | 0.2–2.5 | NA | 0.97 (0.92, 1.03) | 0.93 (0.82, 1.05) | 0.99 (0.92, 1.06) | 0.45 | 29.0 | 6
| | 0.1 | | 0.93 (0.82, 1.05) | 0.99 (0.92, 1.07) | 0.42 | 25.4 | 6
| | 0.2 | | 0.93 (0.83, 1.04) | 1.00 (0.92, 1.08) | 0.40 | 22.6 | 6
| | 0.3 | | 0.93 (0.83, 1.04) | 1.00 (0.92, 1.09) | 0.38 | 20.3 | 6
| | 0.4 | | 0.93 (0.84, 1.03) | 1.01 (0.92, 1.10) | 0.36 | 18.4 | 6
| | 0.5 | | 0.93 (0.85, 1.03) | 1.01 (0.92, 1.11) | 0.35 | 17.0 | 6
| | 0.6 | | 0.94 (0.85, 1.03) | 1.01 (0.92, 1.12) | 0.35 | 16.2 | 6
| | 0.7 | | 0.94 (0.86, 1.02) | 1.02 (0.91, 1.13) | 0.34 | 15.4 | 6
| | 0.8 | | 0.94 (0.87, 1.02) | 1.02 (0.91, 1.13) | 0.35 | 16.0 | 6
| | 0.9 | | 0.95 (0.88, 1.02) | 1.02 (0.91, 1.14) | 0.35 | 20.9 | 6
| | 1.0 | | 0.95 (0.88, 1.02) | 1.02 (0.91, 1.16) | 0.37 | 25.1 | 5
| | 1.1 | | 0.95 (0.89, 1.02) | 1.02 (0.89, 1.17) | 0.43 | 27.6 | 5
| | 1.2 | | 0.93 (0.82, 1.05) | 0.99 (0.92, 1.06) | 0.45 | 29.0 | 6
| | 1.3 | | 0.93 (0.82, 1.05) | 0.99 (0.92, 1.07) | 0.42 | 25.4 | 6
| | 1.4 | | 0.93 (0.83, 1.04) | 1.00 (0.92, 1.08) | 0.40 | 22.6 | 6

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), ALA = alphalinolenic acid, CHD = coronary heart disease, ES = effect size, NA = not applicable.

For both EPA and DHA, separately, two studies evaluated associations with CHD, both at about 10 years of followup (Figure 19, plots #84 & 93). Spanish EPIC found no associations between DHA or EPA intake and CHD in either men or women (analyzed separately).172 MESA found near-significant associations (P=0.09 DHA and 0.06 EPA) between higher DHA and EPA intake and lower risk of CHD.171

Only MESA evaluated DPA intake, finding significantly lower risk of CHD among those with higher DPA intake after 10 years of followup (Figure 19, plot #87).171

Seven studies evaluated intake of EPA+DHA (five studies) or EPA+DHA+DPA (two studies) with 6 to 23 years of followup (Alpha-Tocopherol Beta-Carotene Cancer Prevention, Glostrup Population Studies, Health Professional Follow-up Study, Japan Public Health Center-Based Study - Cohort I, MESA, Nurses’ Health Study, Spanish EPIC) (Figure 19, plots #90 & 91). Individually, studies found variable associations. In two analyses of combined men and women (Japan Public Health Center-Based Study - Cohort I, MESA), neither found a significant association at 10 and 11.5 years of followup (although, MESA found a lower risk with higher EPA+DHA+DPA intake at P=0.08).84, 171 Three studies analyzed associations in women specifically (Glostrup Population Studies, Nurses’ Health Study, Spanish EPIC). The Nurses’ Health Study and Glostrup Population Studies found significantly lower risk of CHD with higher EPA+DHA intake;69, 135 the Spanish EPIC study also found lower HRs with higher intake but the association was nonsignificant.172 Four studies analyzed men specifically (Alpha-Tocopherol Beta-Carotene Cancer Prevention, Glostrup Population Studies, Health Professional Follow-up Study, Spanish EPIC). All found no significant associations; however, in contrast with the studies of all adults or of women, the direction of the associations suggested higher risk of CHD among men with higher marine oil intake at baseline.54, 57, 135, 172

By meta-analysis (Table 20), overall there no significant association between marine oil intake and CHD across a median dose range of 0.038 to 3.47 g/d (effect size per g/d = 0.94; 95% CI 0.81 to 1.10). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.4 g/d) consistently found a stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1, ES above know about 1). At all knot points the differences were nonsignificant. This weakly suggests the possibility of a floor effect (where intake above a certain minimum amount is needed before any benefit accrues). The best fit curve was found with a knot at 0.4 g/d. The P values for differences between lower- and higher-dose knots were between 0.12 and 0.14 at all knots ≥0.3 g/d.

Table 20 Meta-analysis results of observational studies of marine oil (EPA+DHA±DPA) intake and CHD

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
178,005 | 0.038–3.47 | NA | 0.94 (0.81, 1.10) | | | | | 9
| | 0.1 | | 0.85 (0.43, 1.69) | 0.91 (0.74, 1.12) | 0.86 | 64.6 | 8
| | 0.2 | | 0.67 (0.38, 1.20) | 1.00 (0.87, 1.15) | 0.20 | 55.5 | 8
| | 0.3 | | 0.74 (0.50, 1.10) | 1.01 (0.88, 1.16) | 0.14 | 47.6 | 7
| | 0.4 | | 0.78 (0.57, 1.09) | 1.02 (0.89, 1.17) | 0.14 | 46.4 | 7
| | 0.5 | | 0.80 (0.60, 1.07) | 1.03 (0.90, 1.18) | 0.12 | 47.9 | 7
| | 0.6 | | 0.82 (0.63, 1.07) | 1.04 (0.91, 1.19) | 0.12 | 51.3 | 7
| | 0.7 | | 0.84 (0.66, 1.07) | 1.06 (0.93, 1.20) | 0.13 | 58.0 | 7
| | 0.8 | | 0.86 (0.69, 1.07) | 1.07 (0.94, 1.21) | 0.13 | 184.7 | 6
| | 0.9 | | 0.88 (0.72, 1.07) | 1.07 (0.94, 1.23) | 0.14 | 79.4 | 5
| | 1.0 | | 0.89 (0.74, 1.07) | 1.08 (0.95, 1.23) | 0.13 | 64.1 | 4
| | 1.1 | | 0.89 (0.74, 1.07) | 1.09 (0.96, 1.25) | 0.13 | 65.7 | 4
| | 1.2 | | 0.90 (0.75, 1.07) | 1.10 (0.95, 1.27) | 0.13 | 67.1 | 4
| | 1.3 | | 0.91 (0.77, 1.07) | 1.11 (0.95, 1.30) | 0.14 | 68.3 | 4
| | 1.4 | | 0.91 (0.77, 1.07) | 1.12 (0.96, 1.32) | 0.12 | 71.5 | 4

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), CHD = coronary heart disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, ES = effect size, NA = not applicable.

#### n-3 FA Biomarkers

Three studies analyzed n-3 FA biomarkers (Cardiovascular Health Study, EPIC Norfolk, MESA) in healthy adults (men and women combined) with 10, 13, and 16 years of followup.149, 159, 171

The two studies that evaluated blood or plasma levels of total n-3 FA combined had conflicting findings regarding the association between total n-3 FA biomarkers and risk of CHD (Figure 19, plots #96 & 97). EPIC Norfolk found no evidence of an association between blood levels of total n-3 FA and risk of CHD at 13 years,149 but the Cardiovascular Health Study found a significantly lower risk of CHD at 16 years with higher total n-3 FA plasma levels.148, 159

All three studies (Cardiovascular Health Study, EPIC Norfolk, MESA) found no association between ALA blood, plasma, or phospholipid levels and risk of CHD (Figure 19, plots #82 & 83).149, 159, 171

All three studies evaluated both EPA and DHA blood, plasma, or phospholipid levels (separately for each n-3 FA) and found similar associations for the two n-3 FA (Figure 19, plots #85, 86, 94, & 95). The Cardiovascular Health Study and MESA both found lower risk of CHD associated with higher baseline EPA and DHA levels.148, 159, 171 EPIC Norfolk found no association.149

The three studies also evaluated DPA blood, plasma, or phospholipid levels, but each study had the opposite findings as for EPA and DHA biomarkers (Figure 19, plots #88 & 89). The Cardiovascular Health Study and MESA found no significant association with CHD (although the HR estimates also favored lower CHD with higher DPA levels).148, 159, 171 EPIC Norfolk found a significantly lower risk of CHD with higher DPA blood levels.149

The MESA study found a significant association between combined EPA+DHA+DPA phospholipid levels and lower risk of CHD (Figure 19, plot #92).171

#### Observational Study Subgroup Analyses

The Pooling Project found a stronger, almost significant, association between ALA intake and incident CHD in men (HR=0.85; 95% CI 0.72 to 1.01) than in women (HR=1.02; 95% CI 0.65 to 1.59), but did not report whether these associations were significantly different from each other (whether there was an interaction).181 The Cardiovascular Health Study found no difference in associations between ALA (plasma or intake) and incident CHD between men and women or between those with higher versus lower (or no) fish intake at baseline.148

## Myocardial Infarction, Total (Fatal and Nonfatal)

### Randomized Controlled Trials

Eleven RCTs evaluated risk of MI (Table 21).48, 49, 51, 81, 87, 90, 96, 123, 146, 157, 160 Of these, one study was conducted in 12,716 generally healthy participants,49 three were in a total of 27,938 participants at risk of CVD (defined as previous stable angina,49 dyslipidemia,90 or a combination of various risk factors,160 and nine were in a total of 29,338 participants with CVD including MI,48, 49, 160 CHD,51, 90 diabetes, and history of CVD,146 all CVD,123 heart failure,96 previous persistent AFib,157 ventricular tachycardia or fibrillation,81 and arrhythmia.87 One of the marine oil trials reported separate analyses for at risk and CVD populations.90 One of the ALA trials reported separate analyses for all three population groups.49 Three of the trials reported incident MI to be a primary outcome (Bosch 2012, Burr 1989, Galan 2010); however Galan recorded MI as a secondary outcome in the ISRCTN registry).48, 123, 146

Table 21 Myocardial infarction: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs Placebo
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | ≤0.85 g (Marine oil) [E:D 0.9–1.5] | Placebo | 0 (Olive oil) | 5 y | Monitored by self-report but compliance level was not reported | 10/6239, 0.2% | 13/6266, 0.2% | HR 0.76 (0.34, 1.74) | 0.52
Yokoyama 2007 17398308 Japan | At risk | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 71/9326 0.8% | 93/9319 1% | HR 0.77 (0.56, 1.05) | 0.091
| At risk (no previous CVD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 40/7503, 0.7% | 51/7478, 0.5% | HR 0.79 (0.52, 1.19) | 0.253
Bosch 2012 22686415 Canada | CVD | EPA+DHA | 0.84 g/d (Marine oil) [E:D 1.24] | Placebo | 0 (Olive oil) | 6+ y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 344/6281, 5.5% | 316/6255, 5.1% | Adj HR 1.09 (0.93, 1.27) | 0.28
Brouwer 2006 16772624 N Europe | CVD | EPA+DHA | 0.96 g n-3 FA (0.464 g EPA, 0.335 g DHA) (Marine oil) [E:D]=1.4 | Placebo | 0 (high-oleic acid sunflower oil) | 1 y | Generally good (76% reported taking 80% pills) based on pill counts and confirmed by biomarkers. | 1/273, 0.4% | 3/273, 1% | OR 0.33 (0.03, 3.20) | 0.339
Galan 2010 21115589 France | CVD | EPA+DHA | 0.6 g/d (Marine oil) [E:D 2] | Placebo | 0 (nd) | 4.7 y | Patient reported (86% reported they took >=80% of allocated treatment) | 51/1253, 4.1% | 53/1248, 4.2% | Adj HR 0.97 (0.66, 1.42) | 0.87
Macchia 2013 23265344 Argentina; Italy | CVD | EPA+DHA | 0.85–0.882 g/d (suppl) [nd] | Placebo | 0 (Olive oil) | 1 y | nd | 1/289, 0.3% | 1/297, 0.3% | HR 1.10 (0.07, 17.9) | nd
Sacks 1995 7759696 U.S. | CVD | EPA+DHA+DPA | 6 g/d (suppl) [E:D 1.5] | Placebo | 0 (Olive oil) | 2.4 y | Pill counts | 1/31, 3.2% | 2/28, 7.1% | OR 0.43 (0.04, 5.06) | 0.505
Raitt 2005 15956633 U.S. | CVD | EPA+DHA | EPA 0.756 g/d, DHA 0.54 g/d (fish oil) [E:D 1.4] | Placebo | 0 (olive oil: 73% oleic acid, 12% ) | 2 y | RBC and plasma n-3 FA levels | 1/100, 1.0% | 3/100, 3.0% | OR 0.33 (0.03, 3.19) | 0.61
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 (nd) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 107/3494, 3.1% | 129/3481, 3.7% | Adj HR 0.82 (0.63, 1.06) | 0.121
Yokoyama 2007 17398308 Japan | CVD (previous CVD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 31/1823, 2.3% | 42/1841, 1.7% | HR 0.75 (0.47, 1.19) | 0.223
| CVD (PAD at any time) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 3/117 2.6% | 4/106 3.8% | OR 0.67 (0.15, 3.07)
Burr 1989 2571009 UK | CVD | Fish advice, either alone or in combination with fiber advice, fat advice, or both fiber and fat advice. | EPA 0.34 g/d (diet) | No fish advice (Fat advice, fiber advice, fiber and fat advice, or no advice) | EPA 0.09 g/d (diet) | 2 y | Compliance was good based on dietary assessments | 127/1015, 12.5% | 149/1018, 14.6% | Adj RR 0.84 (0.66, 1.07) | 0.162
ALA vs Placebo
Natvig 1965 5756076 Norway | Healthy | ALA | ALA 5.2 g/d (Linseed oil) | Control oil | ALA 0.13 g/d (Sunflower seed oil) | 1 y | nd | 52/6352, 0.8% | 53/6364, 0.8% | OR 0.99 (0.67, 1.45) | NS
| At risk | ALA | ALA 5.2 g/d (Linseed oil) | Control oil | ALA 0.13 g/d (Sunflower seed oil) | 1 y | nd | 2/216, 0.9% | 12/236, 5.1% | OR 0.17 (0.04, 0.79) | 0.02
| CVD | ALA | ALA 5.2 g/d (Linseed oil) | Control oil | ALA 0.13 g/d (Sunflower seed oil) | 1 y | nd | 9/122, 7.4% | 10/116, 8.6% | OR 0.84 (0.33, 2.16) | 0.724

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, NS = not significant, OR = odds ratio, PAD = peripheral artery disease, PMID = PubMed Identification number, RBC = red blood cell, RCT = randomized controlled trial, RR = relative risk.

#### Marine Oil Versus Placebo

Meta-analysis of the 11 RCTs of marine oil versus placebo yielded a significant summary effect size for lower risk of MI: HR=0.88 (95% CI 0.77 to 1.02) (Figure 20).

Figure 20 Myocardial infarction: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, n/N = number with outcome/number analyzed, n-3 FA = omega-3 fatty acids, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure presents a meta-analysis of 11 randomized control trials that examine the effect of marine oil versus placebos and incident of myocardial infarction. The results come from two studies that examined patients at risk for CVD and nine studies of CVD patients. The overall summary 0.88 (0.77, 1.02) was nonsignificant. Net differences across studies were mostly homogeneous.

##### At-Risk-for-CVD Population

Two RCTs comparing marine oils to control were conducted in participants at increased risk of CVD.90, 160 One compared 1.8 g/d EPA combined with statin with control (statin alone) in 14,981 participants with dyslipidemia (without CHD),90 and one compared marine oil (EPA+DHA) with placebo (olive oil) in 12,505 participants with a combination of various risk factors.160 Compliance was not reported in either study. After 5-year followup, the EPA (and statin) study showed no significant additive effect of EPA on statin use to reduce the risk of MI compared with statin alone (HR 0.79; 95% CI 0.52 to 1.19). In the RCT of EPA+DHA,160 the dose of EPA+DHA was less than 0.85 g/d with a EPA to DHA ratio between 0.9 and 1.5. After 5-year followup, this study found that EPA+DHA had no significant effect on risk of MI compared with placebo (HR 0.76; 95% CI 0.34 to 1.74)

Subgroup meta-analysis (as part of a meta-analysis of all marine oil vs. placebo trials) yielded a nonsignificant summary HR of 0.77 (95% CI 0.57 to 1.03) for people at increased risk for CVD.

##### CVD Population

Nine RCTs of participants with a history of CVD evaluated EPA+DHA supplementation or fish advice to placebo (or no fish advice) in a total of 28,314 participants.48, 51, 81, 87, 90, 96, 123, 146, 157 Followup duration ranged from 1 to over 6 years. Among the nine EPA+DHA trials, total dose of marine oil ranged from 0.6 to 6 g/d; the fish advice trial compared 0.34 g/d (based on food frequency questionnaire) to 0.09 g/d. Among five of the RCTs, the ratio of EPA to DHA ranged from 0.83 to 2. None of the trials found a statistically significant effect of marine oil on risk of MI, with effect sizes ranging from 0.33 (95% CI 0.03 to 3.19) to 1.10 (95% CI 0.07 to 17.9). The RCT that compared 1.8 g/d EPA ethyl ester plus statin with statin alone also analyzed the 3,884 patients with either CHD or peripheral artery disease separately. Followup time was 5 years and compliance was not reported. There was no significant additive effect of EPA supplementation on risk of MI (HR 0.75; 95% CI 0.47 to 1.19 and OR 0.67; 95% CI 0.15 to 3.07).90

Across the nine RCTs of CVD populations, the summary HR (Figure 20) was 0.91 (0.78 to 1.06); almost identical to the near-significant summary HR for all RCTs, regardless of population (HR 0.88; 95% CI 0.77 to 1.02).

#### ALA Versus Placebo

##### Healthy Population

A single trial from 1965 compared linseed oil (ALA 5.2 g/d) to sunflower seed oil (ALA 0.13 g/d) in 12,716 healthy adults. After 1 year of followup, no effect of ALA was found on risk of MI (OR=0.99; 95% CI 0.67 to 1.45).49

##### At-Risk-for-CVD Population

The same trial from 1965 compared linseed oil (ALA 5.2 g/d) to sunflower seed oil (ALA 0.13 g/d) in 452 adults with previous angina pectoris but no infarction. After 1 year of followup, those on ALA supplementation had a significantly lower risk of MI (OR=0.17; 95% CI 0.04 to 0.79).49

##### CVD Population

One ALA trial from the 1960s reported analyses of the effect of ALA in participants with a history of MI in a total of 438 people. The trial used linseed oil as the source of ALA (5.2 g/d) compared with sunflower seed oil (0.13 g/d ALA). It found no significant effect of ALA on risk of a subsequent MI (OR 0.84).49

#### RCT Subgroup Analyses

One trial of EPA+DHA 0.6 g/d versus placebo, in 2501 people with a history of any CVD found no difference in effect on risk of MI of marine oil in participants also taking B vitamins or not.123

Meta-regression of the marine oil trials found no significant interaction between n-3 FA dose (P=0.09) or between at risk and CVD populations (P=0.40), but a significant interaction was found for followup time (P<0.01).

### Observational Studies

Three studies evaluated the associations between n-3 FA intake or biomarker level and MI risk in healthy adults, mostly men, in 4 to 11. 5 years (Appendix F, Myocardial Infarction section; Figure 21).50, 52, 54, 84, 191 Most analyses found no association. The Physicians Health Study found no association between intake of total n-3 FA (combined) and risk of MI in healthy men at 4 years of followup (Figure 21, plot #99). The two studies that evaluated marine oil (EPA+DHA) intake had different findings (Figure 21, plot #98). The Health Professional Follow-up Study found no significant association among healthy men at 6 years of followup.54 The Japan Public Health Center-Based Study - Cohort I study found lower risk of MI among healthy adults (men and women combined) with higher EPA+DHA intake.84

Figure 21 n-3 FA associations with myocardial infarction: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for myocardial infarction. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, black squares = healthy males.

Abbreviations: DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure presents individual plots of the association of omega-3 fatty acid intake or biomarkers with incident myocardial infarction from three longitudinal observational studies. The measures of omega-3 fatty acids include EPA+DHA intake grams per day and total omega-3 fatty acid intake grams per day. Most analyses found no association.

Only the Physicians Health Study evaluated associations of n-3 FA biomarkers and MI. The study found no associations with cholesteryl ester or phospholipid levels of EPA, DHA, or combined EPA+DHA.

## Revascularization

### Randomized Controlled Trials

Six RCTs evaluated coronary revascularization as an outcome (Table 22).67, 81, 90, 121, 123, 146 Of these, one was conducted in 18,645 hypercholesterolemic participants (19.5% with CHD),90 and five were in a total of 20,669 participants with CVD including diabetes and history of CVD,146 all CVD,123 patients with implantable defibrillators,81 and MI.67, 121 None of the trials reported revascularization to be a primary outcome.

Table 22 Revascularization: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | Outcome Definition | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs Placebo
Yokoyama 2007 17398308 Japan | At risk | EPA | 1.8 g/d (Ethyl ester) | Placebo | 0 | CABG or PCTA | 5 y | nd | 191/9326, 2% | 222/9319, 2% | HR 0.86 (0.71, 1.05) | 0.135
| At risk (no previous CVD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | CABG or PCTA | 5 y | Local physicians monitored but compliance level was not reported | 64/7503, 0.9% | 74/7478, 1.0% | HR 0.87 (0.62, 1.21) | 0.40
Rauch 2010 21060071 Germany | CVD | EPA+DHA | 0.46 g EPA, 0.38 g DHA (Marine oil) [E:D=1.2] | Placebo | 0 (Olive oil) | Coronary revascularization | 1 y | Pill counts at 3 mo and 12 mo (≥70% of study period) | ~530/1919, 28% | ~541/1885, 29% | OR 0.93 (0.80, 1.08)
Raitt 2005 15956633 U.S. | CVD | EPA+DHA | EPA 0.756 g/d, DHA 0.54 g/d (fish oil) [E:D 1.4] | Placebo | 0 (olive oil: 73% oleic acid, 12% ) | Coronary revascularization | 2 y | RBC and plasma n-3 FA levels | 2/100, 2.0% | 4/100, 4.0% | OR 0.49 (0.09, 2.74) | 0.68
Bosch 2012 22686415 Canada | CVD | EPA+DHA | 0.84 g/d (Marine oil) [E:D 1.24] | Placebo | 0 (Olive oil) | Coronary, carotid, aortic, or peripheral revascularization | 6+ y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 866/6281, 14% | 869/6155, 14% | HR 0.96 (0.87, 1.05) | 0.39
Galan 2010 21115589 France | CVD | EPA+DHA | 0.6 g/d (Marine oil) [E:D 2] | Placebo | 0 (nd) | Coronary or peripheral revascularization | 4.7 y | Patient reported (86% reported they took >=80% of allocated treatment) | 152/1253, 12% | 156/1248, 13% | HR 0.97 (0.78, 1.22) | 0.82
Nilsen 2001 11451717 Scandinavia | CVD | EPA+DHA | 1.7–1.764 g/d (Marine oil) [E:D 0.5] | Placebo | 0 (Corn oil) | Coronary (implied) revascularization | Median 2.4 y | nd (82% in fish oil group; 86% in the placebo group) | 54/150, 36% | 57/150, 39% | OR 0.92 (0.57, 1.47)
Yokoyama 2007 17398308 Japan | CVD (previous CVD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | CABG or PCTA | 5 y | Local physicians monitored but compliance level was not reported | 127/1823, 7.0% | 148/1841, 8.0% | HR 0.87 (0.69, 1.1) | 0.243
| CVD (PAD at any time) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | CABG or PCTA | 5 y | Local physicians monitored but compliance level was not reported | 6/117 5.1% | 12/106 11.3% | HR 0.40 (0.14, 1.05) | 0.064

Abbreviations: CABG = coronary artery bypass grafting, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, OR = odds ratio, PCTA = percutaneous transluminal coronary angioplasty, PMID = PubMed Identification number, RBC = red blood cell, RCT = randomized controlled trial.

#### Marine Oil Versus Placebo

##### At-Risk-for-CVD Population

Among 18,645 hypercholesterolemic participants (19.5% with CHD), one RCT compared 1.8 g/d EPA ethyl ester combined with statin with control (statin alone) for a duration of 5 years.90 Adherence was not reported. There was no significant difference in the risk of coronary artery bypass between the two groups (HR=0.86; 95% CI 0.71 to 1.05). A subgroup analysis among 14,981 hypercholesterolemic participants without previous CHD showed similar finding (HR=0.87; 95% CI 0.62 to 1.21).

##### CVD Population

Among participants with CVD, five studies compared marine oil (EPA+DHA) to placebo (olive oil or corn oil) in a total of 19,241 participants.67, 81, 121, 123, 146. The dose of EPA+DHA ranged from 0.6 to 1.7 g/d, and the EPA to DHA ratio ranged from 0.5 to 2. Reported in three studies, compliance was more than 70 percent. The mean duration of followup ranged from 1 to more than 6 years. All five studies found that EPA+DHA supplementation had no significant effect on revascularization compared with placebo with HR/OR ranging from 0.49 to 0.97.

One other study compared 1.8 g/d EPA ethyl ester combined with statin with control (statin alone) in a subgroup of 3664 patients with previous CVD (HR=0.87; 95% CI 0.69 to 1.1) and 283 peripheral artery disease patients (HR=0.40; 95% CI 0.14 to 1.05) also did not find significant effect on the risk of coronary artery bypass.90

### Observational Studies

Only the Health Professional Follow-up Study analyzed coronary revascularization (Appendix F, Coronary artery bypass graft surgery section; Figure 22).54 The study found no significant association in healthy men between intake of combined EPA+DHA and risk of undergoing coronary artery bypass grafting after 6 years of followup (P=0.09).

Figure 22 n-3 FA associations with coronary revascularization: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles.

White squares = healthy males

Abbreviations: DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure presents individual plot of the one longitudinal observational study that examined the association of omega-3 fatty acid intake or biomarkers with coronary revascularization. The measures of omega-3 fatty acids include EPA+DHA intake grams per day. The study found non-significant association (P=0.09).

## Acute Coronary Syndrome

### Randomized Controlled Trials

No RCT evaluated acute coronary syndrome.

### Observational Studies

One study (Diet, Cancer, Health) evaluated the associations between multiple n-3 FA measures and acute coronary syndrome (MI or unstable angina) after a mean of 7.6 years in a healthy population (age 50–64 y) (Appendix F, Acute coronary syndrome section; Figure 23).134 Analyses were conducted separately for men and women; for DHA, DPA, EPA, and EPA+DHA+DPA; and for each n-3 FA type, both intake and adipose tissue percent FA. For both men and women, the intake levels of total n-3 FA were not associated with future acute coronary ischemia (Figure 23, plots #102, 104, 106, & 108). Among men, higher baseline adipose tissue DHA, DPA, and EPA+DHA+DPA, but not EPA, were significantly associated with decreased risk of acute coronary ischemia, based on both a 0.1 percent increase in baseline measure and comparing the highest and lowest quantiles for each n-3 FA adipose tissue level (Figure 23, plots #101 103, 105, & 107). Among women, no statistically significant associations between baseline biomarker level and outcome were found.

Figure 23 n-3 FA associations with acute coronary syndrome: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White squares = healthy males, black squares = healthy females.

Abbreviations: DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure presents individual plots of the estimate hazard ratio and association of omega-3 fatty acid intake or biomarkers with acute coronary syndrome from longitudinal observational studies. The measures of omega-3 fatty acids include DHA adipose tissue percent fatty acid, DHA intake grams per day, DPA adipose tissue percent fatty acid, DPA intake grams per day, EPA+DHA+DPA adipose tissue percent fatty acid, EPA+DHA+DPA intake grams per day, EPA adipose tissue percent fatty acid, EPA intake grams per day. These plots replicate results reported in Appendix F.

## Angina Pectoris

### Randomized Controlled Trials

Seven trials evaluated angina pectoris (Table 23). Three RCTs evaluated stable angina,49, 86, 87, 146, one evaluated hospitalization for angina,81 and three evaluated unstable angina.51, 67, 90 Only one trial reported unstable angina to be a primary outcome (Sacks 1995).51 Meta-analysis was not conducted due to the heterogeneity of specific outcomes analyzed by the primary studies.

Table 23 Angina pectoris: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | Outcome Definition | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Yokoyama 2007 17398308 Japan | At risk (dyslipidemia) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | Unstable Angina | 5 y | Local physicians monitored compliance at every clinic visit (nd) | 147/9326, 1.6% | 193/9319, 2.1% | HR 0.76 (0.62, 0.95) | 0.014
| At risk (no previous CVD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | Unstable Angina | 5 y | Local physicians monitored but compliance level was not reported | 59/7503, 0.8% | 70/7478, 0.9% | HR 0.85 (0.60, 1.19) | 0.338
Bosch 2012 22686415^§^ Canada | CVD (or diabetes) | EPA+DHA | 0.84 g/d (Marine oil) [E:D 1.24] | Placebo | 0 (Olive oil) | Angina included new, worsening, or unstable disease | 6+ y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 724/6281, 11.5% | 725/6255, 11.6% | HR 1.00 (0.90, 1.10) | 0.94
Brouwer 2006 16772624 N. Europe | CVD | EPA+DHA | 0.96 g n-3 FA (0.464 g EPA, 0.335 g DHA) (Marine oil) [E:D]=1.4 | Placebo | 0 (high-oleic acid sunflower oil) | Angina | 1 y | Generally good (76% reported taking 80% pills) based on pill counts and confirmed by biomarkers. | 10/273, 4% | 12/273, 4% | OR 0.83 (0.35, 1.95) | nd
Nilsen 2001 11451717 | CVD | EPA+DHA | 3.52 g/d (marine oil) [E:D 2] | Placebo | 0 (Corn oil) | Unstable Angina | Median 2.4 y | nd | 32/150, 21.3% | 28/150, 18.7% | OR 1.18 (0.67, 2.08) | 0.564
Raitt 2005 15956633 U.S. | CVD | EPA+DHA | EPA 0.756 g/d, DHA 0.54 g/d (fish oil) [E:D 1.4] | Placebo | 0 (olive oil: 73% oleic acid, 12% ) | Hospitalization for angina | 2 y | RBC and plasma n-3 FA levels | 10/100, 10.0% | 7/100, 7.0% | OR 1.48 (0.54, 4.05) | 0.61
Sacks 1995 7759696 | CVD | EPA+DHA+DPA | 6 g/d (suppl) [E:D 1.5] | Placebo | 0 (Olive oil, potassium tablets) | Unstable Angina | 2.4 y | Mean compliance determined by pill count | 3/31, 9.6% | 4/28, 14.3% | OR 0.64 (0.13, 3.16) | 0.59
Yokoyama 2007 17398308 Japan | CVD (previous CVD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | Unstable Angina | 5 y | Local physicians monitored but compliance level was not reported | 88/1823, 4.8% | 123/1841, 6.7% | HR 0.72 (0.55, 0.95) | 0.019
| CVD (PAD at any time) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | Unstable Angina | 5 y | Local physicians monitored but compliance level was not reported | 5/117 4.3% | 8/106 7.5% | HR 0.56 (0.17, 1.71) | 0.310
ALA vs. Placebo
Natvig 1968 5756076 Norway | Healthy | ALA | ALA 5.2 g/d (Linseed oil) | Control oil | ALA 0.13 g/d (Sunflower seed oil) | Stable Angina | 1 y | Participating physicians assessed compliance at follow-up (nd) | 19/6641, 0.29% | 12/6627, 0.18% | OR 1.58 (0.77, 3.26) | 0.214

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, OR = odds ratio, PAD = peripheral artery disease, PMID = PubMed Identification number, RBC = red blood cell, RCT = randomized controlled trial.

#### Marine Oil Versus Placebo

##### At-Risk-for-CVD Population

One study compared 1.8 g/d purified EPA combined with statin with control (statin alone) to placebo with statin in 18,645 participants with dyslipidemia (19.5% with CHD).90 Adherence was verified by local physicians at every clinic visit but the level was not reported. After 5 years of followup, the trial found a significant risk reduction in unstable angina pectoris events (HR 0.76 95% CI 0.62 to 0.95) in participants who were assigned to the EPA+statin group compared to those in the statin alone group.

##### CVD Population

Five trials were conducted in a total of 13,641 patients with documented CVD, CHD or MI.51, 67, 81, 86, 146 The dose of EPA+DHA ranged from 0.84 to 6 g/d, and the EPA to DHA ratio ranged from 1.24 to 2. Reported in two studies, compliance was more than 80 percent, and one study used n-3 FA biomarkers to monitor the adherence. The mean duration of followup ranged from 1 to more than 6 years. All five studies found that EPA+DHA supplementation had no significant effect on the risk for angina compared with placebo with HR/OR ranging from 0.64 to 1.18.

One other study compared 1.8 g/d EPA ethyl ester combined with statin with control (statin alone) found that EPA had significant additive effect on reducing the risk of unstable angina in a subgroup of 3664 patients with previous CVD (HR=0.72; 95% CI 0.55 to 0.95), but the effect was not significant in a subgroup of 283 peripheral artery disease patients (HR=0.56; 95% CI 0.17 to 1.71).90

#### ALA Versus Placebo

##### Healthy Population

One trial compared linseed oil (5.2 g/d ALA) to a control oil (sunflower seed oil, 0.13 g/d ALA) for a duration of 1 year among 13,628 generally healthy participants.49 Adherence was verified at follow-up by participating physicians but level was not reported. This study found no significant effect on stable angina between the two groups (OR 1.58 95% CI 0.77 to 3.26).

### Observational Studies

No observational studies evaluated angina pectoris, per se.

## Stroke, Total (Ischemic and Hemorrhagic, Fatal and Nonfatal)

### Randomized Controlled Trials

Eight RCTs evaluated total stroke (Table 24).49, 51, 70, 90, 96, 123, 146, 157 One was conducted in 13,406 healthy participants,49 18,645 participants with dyslipidemia (19.5% with CHD),90, and the other six included a total of 33,981 participants with CVD and/or diabetes,123, 146 MI,51, 70 persistent AFib,157 and heart failure.96 None of the trials reported total stroke to be a primary outcome.

Table 24 Stroke, total: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs Placebo
Yokoyama 2007 17398308 Japan | At risk (dyslipidemia) | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 166/9326, 1.8% | 162/9319, 1.7% | 1.02 (0.91, 1.13) | 0.785
| At risk (no previous CHD) | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 133/8841 1.5% | 114/8862 1.3% | HR 1.08 (0.95, 1.22) | 0.244
| CVD (previous CHD) | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 33/485 6.8% | 48/457 10.5% | HR 0.80 (0.64, 0.997) | 0.047
Bosch 2012 22686415 Canada | CVD | EPA+DHA | EPA 0.465 g/d, DHA 0.375 g/d (marine oil) [E:D 1:1.24] | Placebo | 0 (Olive oil) | ≥6 y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 314/6281, 5.0% | 336/6255, 5.4% | HR 0.92 (0.79, 1.08) | 0.32
Galan 2010 21115589 France | CVD | EPA+DHA | 0.6 g/d (Marine oil) [E:D 2:1] | Placebo | 0 (nd) | 4.7 y | Patient reported (86% reported they took >=80% of allocated treatment) | 29/1253, 2.3% | 28/1248, 2.2% | HR 1.04 (0.62, 1.75) | 0.88
Marchioli 2002 11997274 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (marine oil) | No intervention | nd | 3.5 y | Followup (adherence was 72.5% at the end of study) | 62/5666, 1.1% | 57/5658, 1.0% | RR 1.22 (0.75, 1.97)
Sacks 1995 7759696 U.S. | CVD | EPA+DHA+DPA | 6 g/d (suppl) [E:D 1.5] | Placebo | 0 (Olive oil) | 2.4 y | Biomarker at followup | 1/31, 3.2% | 0/28, 0% | OR 2.8 (0.11, 71.63)
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 1:1.2] | Placebo | 0 (nd) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 122/3494, 3.5% | 103/3481, 3.0% | HR 1.16 (0.89, 1.51) | 0.271
Macchia 2013 23265344 Argentina and Italy | CVD | EPA+DHA | 0.85–0.882 (suppl) [nd] | Placebo | 0 (Olive oil) | 1 y | nd | 3/289, 1.0% | 3/297, 1.0% | HR 1.16 (0.23, 5.78)
Yokoyama 2007 17398308 Japan | CVD (previous CHD) | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 33/485 6.8% | 48/457 10.5% | HR 0.80 (0.64, 0.997) | 0.047
ALA vs Placebo
Natvig 1968 5756076 Norway | Healthy | ALA | 5.2 g/d (linseed oil) | Control oil | ALA 0.13 g/d (Sunflower seed oil) | 1 y | nd | 12/6716, 0.2% | 9/6690, 0.1% | OR 1.33 (0.56, 3.16) | NS

Abbreviations: ALA = alphalinolenic acid, CHD = coronary heart disease, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, OR = odds ratio, PMID = PubMed Identification number, RR = relative risk.

#### Marine Oil Versus Placebo

Meta-analysis of the seven RCTs of marine oil versus placebo yielded a nonsignificant summary effect size for risk of MI: HR=0.98 (95% CI 0.88 to 1.09) (Figure 24).51, 70, 90, 96, 123, 146, 157

Figure 24 Total stroke: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, n/N = number with outcome/number analyzed, n-3 FA = omega-3 fatty acids, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure presents meta-analysis results for total stoke in randomized controls that looked at comparisons between marine oil omega-3 fatty acid intake versus a placebo. The meta-analysis was conducted for the cardiovascular disease population (seven studies). The overall summary 0.98 (0.88, 1.09) was nonsignificant. Net differences across studies were mostly homogeneous.

##### At-Risk-for-CVD Population

One study compared 1.8 g/d purified EPA combined with statin with control (statin alone) to placebo with statin in 18,645 participants with dyslipidemia (19.5% with CHD).90 Adherence was verified by local physicians at every clinic visit but the level was not reported. After 5 years of followup, the trial did not find significant difference in the risk of total stroke between participants who were assigned to the EPA+statin group and those in the statin alone group (HR=1.02; 95% CI 0.91 to 1.13).

##### CVD Population

Seven RCTs of participants with a history of CVD evaluated EPA±DHA supplementation.51, 70, 90, 96, 123, 146, 157 Followup duration ranged from 1 to at least 6 years. The total dose of marine oil ranged from 0.6 to 6 g/d. Among four of the studies the EPA to DHA ratio ranged from 0.8 to 2. The six studies of EPA+DHA found a statistically significant effect of marine oil on risk of stroke, mostly with wide confidence intervals, and with effect sizes ranging from 0.92 (95% CI 0.79 to 1.08) to 2.8 (95% CI 0.11 to 71.6). The one study that compared 1.8 g/d EPA ethyl ester combined with statin with control (statin alone) found that EPA had significant additive effect on reducing the risk of total stroke in a subgroup of 942 patients with previous CHD (HR=0.80; 95% CI 0.64 to 0.997).90

Across the seven RCTs of CVD populations, the summary HR (Figure 24) was 0.97 (95% CI 0.83 to 1.13).

#### ALA Versus Placebo

##### Healthy Population

One RCT of 13,406 healthy participants compared linseed oil (5.2 g/d ALA) to a control oil (sunflower seed oil with 0.13 g/d ALA).49 Adherence was not reported. After 1 year of follow up, the trial found no significant effect of ALA on stroke (OR=1.33; 95% CI 0.56 to 3.16).

#### RCT Subgroup Analyses

Meta-regression of the marine oil trials found no significant interaction between n-3 FA dose (P=0.06), followup time (P=0.08), or between at risk and CVD populations (P=0.08)

### Observational Studies

Six studies evaluated the associations between n-3 FA intake or biomarker level and risk of total stroke in healthy adults in 4 to 16 years (Appendix F, Stroke section; Figure 25).50, 65, 73, 138, 143, 145, 159, 186 Most analyses found no association between n-3 FA intake and total stroke risk and all found no significant association with n-3 FA biomarker level.

Figure 25 n-3 FA associations with total stroke: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females.

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure presents individual plots of the association of omega-3 fatty acid intake or biomarkers with total stroke from longitudinal observational studies. The measures of omega-3 fatty acids include ALA intake grams per day, ALA plasma percent plasma phospholipid fatty acid, DHA plasma percent plasma phospholipid fatty acid, DPA plasma percent plasma phospholipid fatty acid, EPA+DHA intake grams per day, EPA plasma percent plasma phospholipid fatty acid, total omega-3 fatty acid intake grams per day, total omega-3 fatty acid plasma percent plasma phospholipid fatty acid. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

All six studies evaluated n-3 FA intake (Cardiovascular Health Study, Health Professional Follow-up Study, MORGEN, Nurses’ Health Study, Physician’s Health Study, Swedish Mammography Study). Among analyses the only significant associations were found in women.

In a study of healthy men, the Physicians Health Study found no significant association between intake of total n-3 FA (combined) and total stroke after 4 years of followup (Figure 25, plot #115)

Three studies evaluated ALA intake (Figure 25, plot #109). Two studies (Cardiovascular Health Study, Swedish Mammography Study) found no significant association after 10 and 12 years. The third study, MORGEN, did not report a P value for trend across quintiles, but found lower risk for stroke in all quintiles (at 10 years) compared with the lowest, the middle three of which were statistically significant (with median intake above about 1.25 g/d).

Four studies evaluated combined EPA+DHA intake (Figure 25, plot #113). Three analyses were conducted in women and two in men. In analyses of women, MORGEN and the Swedish Mammography Study found significant associations between higher EPA+DHA (particularly with median intake of at least 0.56 g/d or >0.19 g/d) and lower risk of stroke at 10 years of followup, but the Nurses’ Health Study found no significant association. Both the Health Professional Follow-up Study and the MORGEN analysis of men found no significant association.

#### n-3 FA Biomarkers

Two studies (Cardiovascular Health Study, MORGEN) evaluated plasma n-3 FA levels in healthy adults at 10 and 16 years. All analyses were not statistically significant. The Cardiovascular Health Study found no association with total n-3 FA plasma levels (combined, Figure 25, plot #116). Both studies found no association with plasma ALA (Figure 25, plot #110). In contrast with all other analyses, MORGEN found a near-significant increased risk (P<0.10) of total stroke among adults with higher EPA+DHA levels measured as a continuous variable (OR=1.16 per percentage unit FA; 95% CI 0.94 to 1.45; P=0.07). The Cardiovascular Health Study found no associations for EPA, DHA, and DPA plasma levels (separately, Figure 25, plots #111, 112, & 114).

By meta-analysis (Table 25), overall there is a statistically significant association between marine oil intake and total stroke across a median dosage range of 0.025 to 0.6 g/d (effect size per g/d = 0.68; 95% CI 0.53 to 0.87). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 0.5 g/d) consistently found a much stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below know less than 1; ES above know greater than 1); although, the difference in effect sizes above and below the knots were never statistically significant This implies a possible ceiling effect ceiling effect (where intake above a certain level adds no further benefit). However, given that the differences between lower and higher dose ES remained large across the range of testable dose thresholds, the actual ceiling dose threshold may be above the analyzable range (i.e., >0.5 g/d). The best fit curve was found with the lowest knot at 0.1 g/d. The P values for differences between lower- and higher-dose effect sizes ranged from 0.14 to 0.20.

Table 25 Meta-analysis results of observational studies of marine oil (EPA+DHA±DPA) intake and total stroke

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
178,249 | 0.025–0.60 | | 0.68 (0.53, 0.87) | | | | | 5
| | 0.1 | | 0.26 (0.07, 0.99) | 0.82 (0.57, 1.19) | 0.14 | 37.1 | 5
| | 0.2 | | 0.35 (0.14, 0.90) | 0.95 (0.55, 1.65) | 0.15 | 38.6 | 5
| | 0.3 | | 0.43 (0.20, 0.91) | 1.16 (0.50, 2.68) | 0.19 | 45.0 | 3
| | 0.4 | | 0.44 (0.21, 0.90) | 2.43 (0.33, 18.0) | 0.20 | 51.7 | 3
| | 0.5 | | 0.58 (0.43, 0.79) | 3.83 (0.38, 38.4) | 0.14 | 59.9 | 2

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, ES = effect size.

#### Observational Study Subgroup Analyses

The Cardiovascular Health Study found no difference in associations of ALA intake or plasma values and total stroke by amount of fish consumption at baseline or by sex. The Health Professional Follow-up Study found no difference in association between EPA+DHA intake and ischemic stroke based on whether participants used fish oil supplements.

## Stroke, Ischemic (Fatal and Nonfatal)

### Randomized Controlled Trials

Two RCTs evaluated ischemic stroke (Table 26).90, 96 One was conducted in 18,645 participants with dyslipidemia (19.5% with CHD) and performed a subgroup analysis in 942 patients with previous CHD,90 and the other was conducted in 6975 participants with heart failure.96 Both trials evaluated n-3 FA ethyl esters. Neither of the trials reported ischemic stroke to be a primary outcome.

Table 26 Stroke, ischemic: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs Placebo
Yokoyama 2007 17398308 Japan | At risk (dyslipidemia) | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 115/9326, 1.2% | 123/9319, 1.3% | 0.97 (0.85, 1.10) | 0.632
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 1:1.2] | Placebo | 0 (nd) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 97/3494, 2.8% | 79/3481, 2.3% | OR 1.23 (0.91, 1.66) | nd
Yokoyama 2007 17398308 Japan | CVD (previous CHD) | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 45/485 9% | 41/457 9% | OR 1.04 (0.67, 1.62) | 0.871

Abbreviations: CHD = coronary heart disease, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, OR = odds ratio, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### At-Risk-for-CVD Population

One study compared 1.8 g/d purified EPA combined with statin with control (statin alone) to placebo with statin in 18,645 participants with dyslipidemia (19.5% with CHD).90 Adherence was verified by local physicians at every clinic visit but the level was not reported. After 5 years of followup, the trial did not find significant difference in the risk of ischemic stroke between participants who were assigned to the EPA+statin group and those in the statin alone group (HR=0.97; 95% CI 0.85 to 1.10).

#### CVD Population

One study of 6975 participants with heart failure compared marine oil ethyl esters (EPA+DHA 0.850–0.882 g/d) with placebo.96 The adherence was about 70% by the end of the 3.9-year study. There was no significant difference in the risk of ischemic stroke between the two groups (OR=1.23; 95% CI 0.91 to 1.66)

One other study compared 1.8 g/d EPA ethyl ester combined with statin with control (statin alone) also did not find significant additive effect of EPA on reducing the risk of ischemic stroke in a subgroup of 942 patients with previous CHD (HR=1.04; 95% CI 0.67 to 1.62).90

### Observational Studies

Five studies evaluated the associations between n-3 FA intake or biomarker level and risk of ischemic stroke in healthy adults after 10 to 22 years of followup (Appendix F, Ischemic stroke section; Figure 26).65, 73, 127, 144, 145, 159, 164, 186 All but one analysis across studies were nonsignificant for an association. All but two analyses across studies were nonsignificant for an association.

Figure 26 n-3 FA associations with ischemic stroke: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females.

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure presents individual plots of the association of omega-3 fatty acid intake or biomarkers with ischemic stroke from longitudinal observational studies. The measures of omega-3 fatty acids include ALA intake grams per day, ALA plasma percent plasma phospholipid fatty acid, DHA plasma percent plasma phospholipid fatty acid, DPA plasma percent plasma phospholipid fatty acid, EPA+DHA+DPA cholesterol ester percent fatty acid, EPA+DHA intake grams per day, EPA+DHA+DPA phospholipid percent fatty acid, EPA plasma percent plasma phospholipid fatty acid, total omega-3 fatty acid plasma percent plasma phospholipid fatty acid. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

The five studies all evaluated n-3 FA intake (Atherosclerosis Risk in Communities Study, Cardiovascular Health Study, Health Professional Follow-up Study, MORGEN, Nurses’ Health Study). All found no association with ischemic stroke. This included two studies of ALA intake (Cardiovascular Health Study, MORGEN) in healthy adults after 10 and 12 years of followup (Figure 26, plot #117), one study of EPA and DHA intake, separately, measured as continuous variables (Atherosclerosis Risk in Communities Study) in healthy adults at 18 years followup, and four studies of combined EPA+DHA intake (Figure 26, plot #122) in one analysis of all healthy adults (Atherosclerosis Risk in Communities Study), two analyses in men (Health Professionals Follow-up Study, MORGEN), and two analyses in women (Nurses’ Health Study, MORGEN).

By meta-analysis (Table 27), overall there is a statistically significant association between higher marine oil intake and lower risk of ischemic stroke across a median dosage range of 0.025 to 0.6 g/d (effect size per g/d = 0.51; 95% CI 0.29 to 0.89). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 0.4 g/d) consistently found a much stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot near or greater than 1). All effect sizes below the knots were statistically significant and all above the knots were nonsignificant. The differences between lower- and higher-dose effect sizes were all statistically significant (P=0.03–0.049). This implies a ceiling effect (where intake above a certain level adds no further benefit). However, it is unclear what the threshold may be, as it may be greater than the highest threshold tested (0.4 g/d). The best fit curve was found with a knot at either 0.3 or 0.4 g/d. The difference between lower-dose and higher-dose ES estimates was statistically significant with a knot at 0.1 g/d.

Table 27 Meta-analysis results of observational studies of marine oil (EPA+DHA±DPA) intake and ischemic stroke

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
143,579 | 0.025–0.60 | | 0.51 (0.29, 0.89) | | | | | 4
| | 0.1 | | 0.05 (0.01, 0.46) | 0.87 (0.41, 1.81) | 0.03 | 34.9 | 4
| | 0.2 | | 0.16 (0.05, 0.53) | 1.17 (0.46, 3.00) | 0.03 | 37.0 | 4
| | 0.3 | | 0.24 (0.09, 0.61) | 1.72 (0.46, 6.50) | 0.049 | 43.2 | 2
| | 0.4 | | 0.25 (0.11, 0.60) | 7.08 (0.55, 90.8) | 0.04 | 48.9 | 2

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, ES = effect size.

#### n-3 FA Biomarkers

Three studies evaluated the association between n-3 FA biomarkers and risk of ischemic stroke (Atherosclerosis Risk in Communities Study, Cardiovascular Health Study, MORGEN) in healthy adults.

The Cardiovascular Health Study found a significant association between plasma levels of total n-3 FA (combined) and lower risk of ischemic stroke in healthy adults ≥65 years of age after 16 years of followup (Figure 26, plot #125).

All three studies found no significant associations between plasma, cholesteryl ester, or phospholipid ALA levels and risk of ischemic stroke in healthy adults after 10, 16, and 22 years of followup (Figure 26, plot #118).

The Atherosclerosis Risk in Communities Study and the Cardiovascular Health Study found no associations between plasma, cholesteryl ester, or phospholipid EPA levels and risk of ischemic stroke in healthy adults after 16 to 22 years of follow-up (Figure 26, plot #124).

The same two studies evaluated DHA biomarkers (Figure 26, plot #119). The Atherosclerosis Risk in Communities Study found that those in the in the highest quintiles of DHA cholesteryl ester and phospholipid levels (separately) had lower risk of ischemic stroke with near-statistical significance (P=0.07 and 0.08, respectively). The Cardiovascular Health Study also found the same association across quintiles with plasma DHA with near statistical significance (P=0.052).

The Cardiovascular Health study also evaluated plasma DPA levels and found no significant association with ischemic stroke (Figure 26, plot #120).

The Atherosclerosis Risk in Communities Study found no significant association with cholesteryl ester or phospholipid EPA+DHA+DPA and ischemic stroke at 22 years of followup (Figure 26, plots #121 & 123), and also with phospholipid EPA+DHA at 18 years. MORGEN, however, found a statistically significant association between higher plasma EPA+DHA and ischemic stroke after 10 years.

#### Observational Study Subgroup Analyses

The Cardiovascular Health Study found no difference in associations of ALA intake or plasma values and ischemic stroke by amount of fish consumption at baseline or by sex.

## Stroke, Hemorrhagic (Fatal and Nonfatal)

### Randomized Controlled Trials

Two RCTs evaluated hemorrhagic stroke (Table 28).90, 96 One was conducted in 18,645 participants with dyslipidemia (19.5% with CHD),90 and the other was conducted in 6975 participants with heart failure.96 Both evaluated n-3 FA ethyl esters. Neither of the trials reported hemorrhagic stroke to be a primary outcomes.

Table 28 Stroke, hemorrhagic: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs Placebo
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 1:1.2] | Placebo | 0 (nd) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 13/3494, 0.4% | 10/3481, 0.3% | OR 1.30 (0.57, 2.96) | nd
Yokoyama 2007 17398308 Japan | At risk (dyslipidemia) | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 49/9326, 0.5% | 39/9319, 0.4% | 1.12 (0.91, 1.39) | 0.272

Abbreviations: Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### At-Risk-for-CVD Population

One study compared 1.8 g/d purified EPA combined with statin with control (statin alone) to placebo with statin in 18,645 participants with dyslipidemia (19.5% with CHD).90 Adherence was verified by local physicians at every clinic visit but the level was not reported. After 5 years of followup, the trial did not find significant difference in the risk of hemorrhagic stroke between participants who were assigned to the EPA+statin group and those in the statin alone group (HR=1.12; 95% CI 0.91 to 1.39).

#### CVD Population

One study of 6975 participants with heart failure compared marine oil ethyl esters (EPA+DHA 0.850–0.882 g/d) with placebo.96 The adherence was about 70% by the end of the 3.9-year study. There was no significant difference in the risk of hemorrhagic stroke between the two groups (OR=1.30; 95% CI 0.57 to 2.96)

### Observational Studies

Five studies evaluated the associations between n-3 FA intake or biomarker levels and risk of hemorrhagic stroke in healthy adults after 10 to 16 years of followup (Appendix F, Hemorrhagic stroke section; Figure 27).65, 73, 112, 143, 145, 159, 186 All but one analysis across studies were nonsignificant for an association.

Figure 27 n-3 FA associations with hemorrhagic stroke: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure presents individual plots of the association of omega-3 fatty acid intake or biomarkers with hemorrhagic stroke from longitudinal observational studies. The measures of omega-3 fatty acids include ALA intake grams per day, ALA plasma percent plasma phospholipid fatty acid, DHA plasma percent plasma phospholipid fatty acid, DPA plasma percent plasma phospholipid fatty acid, EPA+DHA intake grams per day, EPA plasma percent plasma phospholipid fatty acid, total omega-3 fatty acid plasma percent plasma phospholipid fatty acid. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

The five studies all evaluated n-3 FA intake (Cardiovascular Health Study, Health Professional Follow-up Study, MORGEN, Nurses’ Health Study, Swedish Mammography Study).

The Cardiovascular Health Study (in adults ≥65 years) and the Swedish Mammography Study in women both found no association between ALA intake and risk of hemorrhagic stroke (Figure 27, plot #126).

Four studies (Health Professional Follow-up Study, MORGEN, Nurses’ Health Study, Swedish Mammography Study) evaluated EPA+DHA intake (Figure 27, plot #130). Only MORGEN, in a subgroup of men (<65 years old), found an association between higher EPA+DHA intake and lower risk of hemorrhagic stroke. No such association was found in women in MORGEN or the other three studies.

By meta-analysis (Table 29), overall there is no significant association between marine oil intake and hemorrhagic stroke across a median dosage range of 0.025 to 0.6 g/d (effect size per g/d = 0.61; 95% CI 0.34 to 1.11). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 0.5 g/d) consistently found similar associations above and below the knots. At no threshold was the difference in effect sizes statistically significant. The best fit curve was found with a knot at 0.1 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at 0.5 g/d (P=0.78).

Table 29 Meta-analysis results of observational studies of marine oil (EPA+DHA±DPA) intake and hemorrhagic stroke

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
178,249 | 0.035–0.6 | | 0.61 (0.34, 1.11) | NA | NA | | | 5
| | 0.1 | NA | 0.55 (0.04, 7.31) | 0.63 (0.27, 1.44) | 0.94 | 49.2 | 5
| | 0.2 | NA | 0.52 (0.14, 1.94) | 0.68 (0.26, 1.81) | 0.79 | 51.1 | 5
| | 0.3 | NA | 0.64 (0.14, 2.90) | 0.55 (0.08, 4.02) | 0.93 | 57.9 | 3
| | 0.4 | NA | 0.63 (0.15, 2.73) | 0.49 (<0.01, 53.9) | 0.93 | 64.0 | 3
| | 0.5 | NA | 0.68 (0.28, 1.63) | 0.17 (<0.01, 1336) | 0.78 | 75.7 | 2

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, ES = effect size, NA = not applicable.

#### n-3 FA Biomarkers

The Cardiovascular Health Study and MORGEN evaluated plasma n-3 FA and risk of hemorrhagic stroke. Both analyses found no significant associations, including total n-3 FA (combined, Cardiovascular Health Study, Figure 27, plot #132); ALA (both studies, Figure 27, plot #126); EPA (Figure 27, plot #131), DHA (Figure 27, plot #128), and DPA (Figure 27, plot #129) (Cardiovascular Health Study); and EPA+DHA (MORGEN).

#### Observational Study Subgroup Analyses

The Cardiovascular Health Study found no difference in associations of ALA intake or plasma values and hemorrhagic stroke by amount of fish consumption at baseline or by sex.

## Sudden Cardiac Death

### Randomized Controlled Trials

Nine RCTs evaluated SCD (Table 30).81, 82, 87, 89, 90, 96, 121, 146, 160 Of these, two studies were conducted in 31,150 participants at risk of CVD (defined as dyslipidemia [19.5% with CHD]90 or with multiple risk factors160), and eight in a total of 24,463 participants with CVD including diabetes and history of CVD,146 arrhythmia,81, 82, 87 MI,89, 121 CHD or peripheral artery disease,90 and heart failure.96 One study reported on both at-risk and CVD populations.90 No trial reported SCD to be a primary outcome.

Table 30 Sudden cardiac death: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs Placebo
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | >= 0.85 g/d (marine oil) [E:D 0.9:1–1.5:1] | Placebo | 0 (Olive oil) | 5 y | Self-reported (nd on level of adherence) | 49/6239 0.8% | 40/6266 0.6% | HR 1.22 (0.80, 1.85) | 0.36
Yokoyama 2007 17398308 Japan | At risk | EPA (+Statin) | 1.8 g/d (Ethyl ester) | Placebo (+Statin) | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 18/9326 0.2% | 17/9319 0.2% | HR 1.06 (0.55, 2.07) | 0.854
| At risk (no previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 4/7503 0.1% | 5/7478 0.1% | HR 1.25 (0.34, 4.67) | 0.736
Bosch 2012 22686415 Canada | CVD | EPA+DHA | EPA 0.465 g/d, DHA 0.375 g/d (Marine oil) [E:D 1.24] | Placebo | 0 (Olive oil) | 6.2 y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 288/6281 4.6% | 259/6255 4.1% | OR 1.10 (0.93, 1.30) | 0.26
Brouwer 2006 16772624 Europe | CVD | EPA+DHA | 0.96 g n-3 PUFA (0.464 g EPA, 0.335 g DHA) (Marine oil) [E:D=1.4] | Placebo | 0 (high-oleic acid sunflower oil) | 1 y | Generally good (76% reported taking 80% pills) based on pill counts and confirmed by biomarkers. | 81/273 29.7% | 90/273 33% | 0.86 (0.6, 1.23) | 0.33
Leaf 2005 16267249 U.S. | CVD | EPA+DHA | 2.6 g/d (Marine oil) | Placebo | 0 (Olive oil) | 1 y | Pill counts and analysis of the phospholipids of red blood cells for their content of EPA and DHA. Noncompliance ~35% | 3/200 1.5% | 1/202 0.5% | 3.06 (0.32, 29.68) | 0.334
Rauch 2010 21060071 Germany | CVD | EPA+DHA | 0.46 g EPA, 0.38 g DHA (Marine oil) [E:D 1.2] | Placebo | 0 (Olive oil) | 1 y | Pill counts at 3 months and 12 months (≥70% of study period) | 28/1919 1.5% | 29/1885 1.5% | 0.95 (0.56, 1.6) | 0.84
Raitt 2005 15956633 U.S. | CVD | EPA+DHA | EPA 0.756 g/d, DHA 0.54 g/d (fish oil) [E:D 1.4] | Placebo | 0 (olive oil: 73% oleic acid, 12% ) | 2 y | RBC and plasma n-3 FA levels | 2/100 2% | 0/100 0% | OR 5.1 (0.24, 107.64) | 0.47
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 (NR) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 307/3494 | 325/3481 | Adj. HR 0.93 (0.79, 1.08) | 0.333
Yokoyama 2007 17398308 Japan | CVD (previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 13/1823 0.7% | 13/1841 0.7% | HR 1.02 (0.47, 2.19) | 0.967
| CVD (PAD at any time) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 5 y | Local physicians monitored but compliance level was not reported | 1/117 0.9% | 4/106 3.8% | HR 0.19 (0.01, 1.33) | 0.099
Burr 2007 17343767 UK | CVD | Fish advice | EPA 0.45 g/d (diet)^a^ | No fish advice | EPA 0.11 (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 49/1109, 4.4% | 47/1543, 3.0% | Adj HR 1.43 (0.95, 2.15) | 0.086
| CVD | EPA+DHA (advice to take fish oil) | EPA ≤0.51 and DHA ≤0.345 (marine oil)^a^ | No fish advice | EPA 0.11 (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 24/462, 5.2% | 47/1543, 3.0% | Adj HR 1.84 (1.11, 3.05) | 0.018
| CVD | EPA+DHA (advice to take fish oil) | EPA ≤0.51 and DHA ≤0.345 (marine oil)^a^ | Fish advice | EPA 0.45 g/d (diet)^a^ | 9 y | dietary charts sent by post with reply-paid envelopes | 24/462, 5.2% | 49/1109, 4.4% | OR 1.19 (0.72, 1.96) | nd

Abbreviations: CHD = coronary heart disease, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, OR = odds ratio, PAD = peripheral artery disease, PMID = PubMed Identification number, RBC = red blood cell, RCT = randomized controlled trial.

#### Marine Oil Versus Placebo

Meta-analysis of the nine trials of marine oil yielded a nonsignificant summary HR=1.04 (95% CI 0.92 to 1.17) (Figure 28).81, 82, 87, 90, 96, 121, 146, 160

Figure 28 Sudden cardiac death: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid

This figure presents meta-analysis results for sudden cardiac death in randomized controls that looked at comparisons between marine oil omega-3 fatty acid intake versus a placebo. The meta-analysis was divided by at risk (two studies) and cardiovascular disease (eight studies) populations. Subgroup meta-analysis of at risk and cardiovascular disease populations yielded a nonsignificant summaries of 1.17 (0.82, 1.67) and 1.03 (0.90, 1.17), respectively. The overall summary 1.04 (0.92, 1.17) was also nonsignificant. Net differences across studies were mostly homogeneous.

##### At-Risk-for-CVD Population

Among people at risk for CVD, one study compared 1.8 g/d EPA ethyl ester combined with statin with control (statin alone) in 18,645 participants with dyslipidemia,90 and one compared marine oil (EPA+DHA) or EPA to placebo in 12,505 participants with multiple risk factors.160 The dose of EPA+DHA was at least 0.85 g/d. Neither study reported adherence level. The durations of followup was 4.6 and 5 years. Both studies found no significant differences in SCD between groups (HR 1.06, 95% CI 0.55 to 2.07; OR 1.28, 95% CI 0.80 to 1.85). Because the study that combined EPA with statin also included a percentage of patients with CHD, the authors reported the results of a subgroup analysis of patients without previous CHD, though the results were still nonsignificant (HR 1.25; 95% CI 0.34 to 4.67).90

Subgroup meta-analysis yielded a nonsignificant summary HR of 1.17 (95% CI 0.82 to 1.67) for people at risk for CVD.

##### CVD Population

Among people with existing CVD, eight studies compared marine oil (EPA+DHA) to placebo (olive oil or oleic acid sunflower oil),81, 82, 87, 89, 90, 96, 121, 146 Overall, these trials followed 24,463 people with existing CVD. The EPA+DHA doses ranged from 0.84 to 2.6 g/d. The duration of followup ranged from 0.8 years to 6.2 years. Compliance, when reported, ranged from 70 to 88 percent. All trials found no significant association, with effect sizes ranging from 0.94 to 3.06.

The study described above that combined 1.8 g/d EPA ethyl ester also reported separate analyses for the patients with CHD and peripheral artery disease at any time. There was no significant additive effect of EPA supplementation on SCD in either group of patients (HR 1.02, 95% CI 0.47 to 2.19; HR 0.19, 95% CI 0.01 to 1.33).90

One study compared two levels of “fish advice” (dietician to advise to increase fish and/or fish oil supplement intake) with no fish advice in a total of 3114 men with MI or angina.89 The mean EPA intake estimated by the dietary assessment was 0.45 and ≤0.85 g/d in the “fish advice” groups, and was 0.11 in the “no fish advice” group. No estimates for DHA intake levels were reported. Compliance was good (fish intake was significantly increased in the “fish advice” groups) based on the dietary assessments. The trial found that, after 9 years of followup, overall, there was no significant difference in SCD between 1109 men with angina who were advised to increase fish intake and 1543 men with angina who were not (adjusted HR 1.43; 95% CI 0.95 to 2.15; P=0.086). The effect was significant in the subgroup of 462 men given advice about taking a fish oil supplement (adjusted HR 1.84, 95% CI 1.11 to 3.05). There was no significant difference between the two groups (OR 1.19; 95% CI 0.72 to 1.96). Across the four RCTs of CVD populations, the summary HR was 1.03 (95% CI 0.92 to 1.17).

#### RCT Subgroup Analyses

No trial reported a direct within-study subgroup analysis. By meta-regression of the marine oil trials, effect sizes did not vary across studies by dose (P=0.93) or population (P=0.48), but did vary across studies by followup time (P=0.04)

### Observational Studies

Four studies evaluated the associations between multiple n-3 FA measures and SCD after about 11 to 18 years of follow-up in mostly healthy adults of varying ages, and also, in one study, women with a history of prior CVD (Appendix F, Sudden coronary death section; Figure 29).60, 78, 83, 84, 159, 186 Analyses and studies found a mix of nonsignificant associations and associations favoring higher n-3 FA quantiles.

Figure 29 n-3 FA associations with sudden cardiac death: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure presents individual plots of the association of omega-3 fatty acid intake or biomarkers with sudden cardiac death from longitudinal observational studies. The measures of omega-3 fatty acids include ALA intake percent kilocalories, ALA intake grams per day, ALA plasma percent plasma phospholipid fatty acid, DHA plasma percent plasma phospholipid fatty acid, DPA plasma percent plasma phospholipid fatty acid, EPA+DHA intake grams per day, EPA plasma percent plasma phospholipid fatty acid, total omega-3 fatty acid intake grams per day, total omega-3 fatty acid plasma percent plasma phospholipid fatty acid. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

The Physician’s Health Study found no association between total n-3 FA intake (combined) and risk of SCD at 11 years in healthy men (Figure 29, plot #140). Two studies analyzed ALA intake (Figure 29, plots #133 & 134). The Nurses’ Health Study found a significant association between higher ALA intake and lower risk of SCD after 18 years. The Cardiovascular Health Study found no significant association with 16 years of followup. The Japan Public Health Center-Based Study - Cohort I also found no association between EPA+DHA intake and risk of SCD at about 11.5 years (Figure 29, plot #138).

#### n-3 FA Biomarkers

The Cardiovascular Health Study found a significant association between plasma levels of total n-3 FA combined (implicitly ALA, DHA, DPA, and EPA) and lower risk of SCD with 16 years of followup (Figure 29, plot #141). The Cardiovascular Health Study, however, found no association between plasma ALA level and risk of SCD (Figure 29, plot #135). Regarding marine oils, this same study found a significant association between plasma DHA (Figure 29, plot #136) and risk of SCD, but no significant associations with plasma DPA (Figure 29, plot #137) or EPA (Figure 29, plot #139).

#### Observational Study Subgroup Analyses

In the Nurses’ Health Study, the subgroup of women with no history of CVD at baseline had a significant association between higher ALA intake and lower risk of SCD after 18 years; in the smaller subgroup of women with a history of CVD, the effect estimates across quintiles were similar, but not statistically significant.83 The Cardiovascular Health Study reported no significant difference (without details) in association of total n-3 FA and SCD between participants with high, low, or no fish consumption and between men and women.186

## Atrial Fibrillation

### Randomized Controlled Trials

Three RCTs evaluated supraventricular tachycardias, specifically AFib.96, 133, 157 All were conducted among people with CVD (Table 31). Specifically, two studies were conducted in a total of 785 people who had previous persistent AFib,133, 157 and one in 5835 heart failure patients without AFib at study entry.96 No study reported AFib to be a primary outcome.

Table 31 Atrial fibrillation: RCTs

Study Year PMID Region | Population | Int (n-3 FA) | Int n-3 Dose (Source) [E:D; n-6:3] | Control | Ctrl n-3 Dose (Source) [E:D; n-6:3] | F/up Time | Compliance Verification | Int n/N, % | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Macchia 2013 23265344 Italy & Argentina | CVD (previous persistent AFib) | EPA+DHA | 0.850–0.882 g/d (marine oil) [E:D 0.5] | Placebo | 0 (Olive oil) | 1 y | NR | 56/297, 18.9% | 69/289, 23.9% | HR 1.28 (0.90, 1.83) | 0.17
Nodari 2011 21844082 Italy | CVD (previous persistent AFib) | EPA+DHA | 0.850–0.882 g/d (marine oil) [E:D 1.2] | Placebo | 0 (Olive oil) | 1 y | NR | 15/100, 15% | 25/99, 25% | OR 0.52 (0.26, 1.06)^a^ | NR
Tavazzi 2008 18757090 Italy | CVD (heart failure, no history of AFib) | EPA+DHA | 0.850–0.882 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 (NR) | 3.9 y | Exam question (~30% not taking n-3 FA or placebo by the end of study) | 444/2921, 15.2% | 408/2914, 14.0% | HR 1.10 (0.96, 1.25) | 0.11

Abbreviations: AFib = atrial fibrillation, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, NR = not reported, OR = odds ratio, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### Marine Oil Versus Placebo

##### CVD Population

Among 785 people with previous persistent AFib, two RCTs compared marine oil (EPA+DHA) to placebo (olive oil).133, 157 The same dose of EPA+DHA (0.850 to 0.882 g/d) was used in both studies for a duration of 1 year, but the EPA to DHA ratio was 0.5 in one study and 1.2 in another. Compliance was not reported. Both studies found that EPA+DHA supplementation had no significant effect on the recurrence of AFib (HR 1.28; 95% CI 0.90 to 1.83; OR 0.52, 95% 0.26 to 1.06).

Among 5835 heart failure patients without AFib at study entry, one RCT compared marine oil ethyl esters (EPA+DHA) to placebo.96 The dose of EPA+DHA was 0.850 to 0.882 g/d with a EPA to DHA ratio of 1.2. Compliance was about 70 percent. This study found no significant effect on incidence of AFib comparing EPA+DHA ethyl esters to placebo after a mean 3.9 years of followup (HR 1.10 95% CI 0.96 to 1.25).96

#### RCT Subgroup Analyses

Two RCTs reported subgroup analysis for AFib (Table 32). In one trial of AFib recurrence in people with a history of persistent AFib,157 no differences in effect were found between subgroups based on sex, age (at a threshold of 60 years), or duration of prior AFib (at a threshold of 48 hours). In the trial of incident AFib (history of heart failure),96 no differences in effect were found between subgroups based on age (threshold 70 years), left ventricular ejection fraction (threshold 40%), ischemic versus nonischemic heart failure, New York Heart Association class (I&II vs. III&IV), diabetes, total cholesterol (200 mg/dL threshold), glomerular filtration rate (60 mL/min threshold), or fish intake (2 servings per week threshold).

Table 32 Atrial fibrillation: Subgroup analyses, randomized trials

Study | Population | Subgroups | n-3 FA | Comparator | N Total | P difference | Difference | Favors
Macchia 2013 23265344 Italy & Argentina | CVD (previous persistent AFib) | Age: <60 vs >= 60 | EPA+DHA | Placebo oil | 586 | 0.12
| | Men vs women | EPA+DHA | Placebo oil | 586 | 0.70
| | Duration of AF <48 hours vs. >= 48 hours | EPA+DHA | Placebo oil | 586 | 0.12
Tavazzi 2008 18757090 Italy | CVD (heart failure, no history of AFib) | Age: <=70 vs. >70 | EPA+DHA | Placebo | 5835 | 0.55
| | LVEF <=40% vs. >40% | EPA+DHA | Placebo | 5835 | 0.46
| | Ischemic etiology vs. nonischemic etiology | EPA+DHA | Placebo | 5835 | 0.95
| | NYHA II vs. NYHA III–IV | EPA+DHA | Placebo | 5835 | 0.55
| | Diabetes vs. no diabetes | EPA+DHA | Placebo | 5835 | 0.51
| | Total cholesterol <=200 mg/dL vs. >200 mg/dL | EPA+DHA | Placebo | 5835 | 0.57
| | eGFR <60 ml/min/1.73 m^2^ vs. >= 60 ml/min/1.73 m^2^ | EPA+DHA | Placebo | 5835 | 0.99
| | History of AFib vs. no history of AFib | EPA+DHA | Placebo | 5835 | 0.24
| | Fish intake <2 per week vs. >= 2 per week | EPA+DHA | Placebo | 5835 | 0.16

Abbreviations: AFib = atrial fibrillation, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EGFR = epidermal growth factor receptor, EPA = eicosapentaenoic acid, LVEF = left ventricular ejection fraction, n-3 FA = omega-3 fatty acids, NYHA = New York Heart Association class, PMID = PubMed Identification number.

### Observational Studies

Five studies evaluated the associations between multiple n-3 FA measures and supraventricular tachycardias (specifically AFib) after 6.4 to 18 years of followup in healthy adults (mostly over age 50 or 65 years) (Appendix F, Atrial fibrillation section; Figure 30).79, 86, 110, 111, 140, 158 Most specific analyses found no significant association and the three studies with significant associations were inconsistent.

Figure 30 n-3 FA associations with atrial fibrillation: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure presents individual plots of the association of omega-3 fatty acid intake or biomarkers with atrial fibrillation from longitudinal observational studies. The measures of omega-3 fatty acids include ALA intake percent fatty acid, ALA plasma percent plasma phospholipid fatty acid, ALA percent serum fatty acid, DHA plasma percent plasma phospholipid fatty acid, DHA percent serum fatty acid, DPA plasma percent plasma phospholipid fatty acid, DPA percent serum fatty acid, EPA+DHA+DPA intake grams per day, EPA+DHA+DPA percent serum fatty acid, and EPA plasma percent plasma phospholipid fatty acid. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

Four studies evaluated n-3 FA intake. The Cardiovascular Health Study found no significant association with ALA intake (Figure 30, plot #142), overall and, separately, in men and women. The other three studies (Women’s Health Initiative, Rotterdam, and the Diet, Cancer, Health study) evaluated marine oil (EPA+DHA±DPA) intake (Figure 30, plot #148). Over a relatively low and narrow range of marine oil intake (less than about 0.3 g/d), the Women’s Health Initiative and Rotterdam studies found no significant association. In contrast, the Diet, Cancer, Health study found that after a mean of 8.1 years, higher EPA+DHA+DPA intake, particularly in the quintile with median intake of 1.3 g/d, was associated with lower risk of AFib in healthy women (age 50 to 64 years).

#### n-3 FA Biomarkers

The Cardiovascular Health Study and the Kuopio Ischemic Heart Disease Risk Factor Study evaluated biomarkers. The Cardiovascular Health Study found significantly lower risks of AFib (after 14 years) with higher plasma levels of total n-3 FA combined (not plotted because median quantile values not reported), and DHA (Figure 30, plot #144) in healthy adults at least 65 years of age. No significant associations were found with plasma ALA (Figure 30, plot #143), DPA (Figure 30, plot #146), or EPA (Figure 30, plot #150). The Kupio study found statistically significant associations for both higher serum fatty acid combined EPA+DHA+DPA (Figure 30, plot #149) and higher serum fatty acid DHA (plot #145) with lower risk of AFib at a mean 17.7 years, but no significant associations for serum fatty acid EPA (Figure 30, plot #151) or DPA (Figure 30, plot #147).

#### Observational Study Subgroup Analyses

In the Cardiovascular Health Study, no differences were found (in a lack of association) for either plasma levels or intake of ALA and AFib between men and women.

## Ventricular Arrhythmia

### Randomized Controlled Trials

One 2-by–2 factorial study evaluated ventricular arrhythmia, described as “ventricular arrhythmia–related events (SCD, fatal and nonfatal cardiac arrest, and placement of implantable cardioverter–defibrillators)” (Table 33).193 The RCT compared the effects of a margarine supplemented with EPA+DHA alone (0.4 g/d), a combination of both EPA+DHA and ALA margarines, and ALA alone (2 g/d) with placebo margarine (oleic acid) in 4837 participants with a history of MI.119 (The 2-by–2 factorial trial reported only analyses of EPA+DHA vs. placebo and ALA vs. placebo.) Ventricular arrhythmia was a secondary outcome in the trial.

Table 33 Ventricular arrhythmia: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N, % | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±ALA) | 0; 2 g/d ALA (Placebo margarine = oleic acid; Plant oil) | 40 mo | 90% of the patients adhered fully to the protocol; verified by biomarkers | 67/2404, 2.8% | 74/2433, 3.0% | HR 0.90 (0.65, 1.26) | 0.55
ALA vs. Placebo
Kromhout 2010 20929341 Netherlands | CVD | ALA | 0.4 g/d EPA+DHA and 2 g/d ALA (Marine; Plant oil) [E:D 3:2] | Placebo (±EPA+DHA) | 0; 0.4 g/d EPA-DHA (placebo = oleic acid; Marine oil) [E:D 3:2] | 40 mo | 90% of the patients adhered fully to the protocol; verified by biomarkers | 62/2409, 2.6% | 79/2428, 3.3% | HR 0.79 (0.57, 1.10) | 0.16

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### Marine Oil Versus Placebo

##### CVD Population

The 2-by–2 factorial trial compared 0.4 g/d of EPA+DHA in margarine to placebo margarine for 40 months with 90 percent compliance, overall.193 The study found no significant effect of marine oil intake on ventricular arrhythmia (HR 0.90; 95% CI 0.65 to 1.26).

#### ALA Versus Placebo

##### CVD Population

The 2-by–2 factorial study compared 2 g/d ALA in margarine to control margarine.193 The trial found no difference in risk of ventricular arrhythmia after 40 months (HR 0.79; 95% CI 0.57 to 1.10).

#### RCT Subgroup Analyses

The same 2-by–2 factorial RCT analyzed subgroups based on history of diabetes (Table 34).193 For patients with diabetes, EPA+DHA supplementation resulted in a nonsignificant halving of ventricular arrhythmia risk (HR=0.51, P=0.09) in contrast to no effect in those without diabetes (HR=1.04, P=0.83); no test for interaction was reported. The effect of ALA on CVD death was significant in patients with diabetes (HR=0.39, P=0.02) and nonsignificant for those without diabetes (HR=0.93, P=0.71).

Table 34 Ventricular arrhythmia: Subgroup analyses, randomized trials

Study Year PMID Region | Population | Subgroups | n-3 FA | Comparator | N Total | P difference | Difference | Favors
Kromhout 2010 20929341 Netherlands | CVD | Diabetes vs. no diabetes | EPA+DHA | Placebo or ALA | 4837 | 0.09 diabetes, 0.83 no diabetes | 0.51 vs. 1.04 | Diabetes (possibly)
| | | ALA | Placebo or EPA+DHA | 4837 | 0.02 diabetes, 0.71 no diabetes | 0.39 vs. 0.93 | Diabetes (possibly)

Abbreviations: ALA = alphalinolenic acid, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, PMID = PubMed Identification number.

### Observational Studies

No observational studies evaluated ventricular arrhythmias, per se.

## Congestive Heart Failure

### Randomized Controlled Trials

Six RCTs evaluated CHF, all of which evaluated marine oils and had as an endpoint CHF hospitalization (Table 35).51, 81, 87, 146, 157, 160 None of the trials reported CHF to be a primary outcome.

Table 35 Congestive heart failure hospitalization: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int n/N,% | Ctrl n/N,% | Effect Size | Reported P value
Marine oil vs. Placebo
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | ≥0.85 g/d (suppl) [E:D 0.9–1.5] | Placebo | 0 (Olive oil) | 5 y | Self-reported (nd on level of adherence) | 96/6239, 5% | 142/6266, 2.3% | HR 0.67 (0.52, 0.87) | 0.002
Bosch 2012 22686415 Canada | CVD | EPA+DHA | 0.84 g/d (Marine oil) [E:D 1.24] | Placebo | 0 (Olive oil) | 6+ y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 331/6281, 5.3% | 320/6255, 5.1% | Adj HR 1.02 (0.88, 1.19) | 0.76
Brouwer 2006 16772624 N. Europe | CVD | EPA+DHA | 0.96 g n-3 FA (0.464 g EPA, 0.335 g DHA) (Marine oil) [E:D]=1.4 | Placebo | 0 (high-oleic acid sunflower oil) | 1 y | Generally good (76% reported taking 80% pills) based on pill counts and confirmed by biomarkers. | 22/273, 8% | 19/273, 7% | OR 1.17 (0.62, 2.22) | nd
Macchia 2013 23265344 Argentina; Italy | CVD | EPA+DHA | 0.85–0.882 g/d (suppl) [nd] | Placebo | 0 (Olive oil) | 1 y | nd | 5/289, 1.7% | 6/297, 2.0% | HR 0.86 (0.26, 2.81) | nd
Raitt 2005 15956633 U.S. | CVD | EPA+DHA | EPA 0.756 g/d, DHA 0.54 g/d (fish oil) [E:D 1.4] | Placebo | 0 (olive oil: 73% oleic acid, 12% ) | 2 y | RBC and plasma n-3 FA levels | 14/100, 14.0% | 12/100, 12.0% | OR 1.19 (0.52, 2.73) | 0.83
Sacks 1995 7759696 U.S. | CVD | EPA+DHA+DPA | 6 g/d (suppl) [E:D 1.5] | Placebo | 0 (Olive oil) | 2.4 y | Pill counting (80% for EPA+DHA; 90% for placebo) | 0/31, 0% | 1/28, 3.6% | nd | nd

Abbreviations: Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, HR = hazard ratio, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, OR = odds ratio, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### Marine Oil Versus Placebo

##### At-Risk-for-CVD Population

Among 12,505 people with multiple risk factors for CHF, one RCT compared marine oil (EPA+DHA) to placebo for a median duration of 5 years.160 The dose of EPA and DHA was at least 0.85 g/d (composition of the marine oil was not reported). Adherence was verified by participants’ self-report but the level of adherence was not reported. The trial found a significant risk reduction in CHF hospitalizations in participants who were assigned to marine oil group compared with those in placebo group (HR 0.67; 95% CI 0.52 to 0.87).

##### CVD Population

Among people with CVD, five RCTs compared marine oil (EPA+DHA) to placebo.51, 81, 87, 146, 157 The RCTs included a total of 13,927 patients. The dose of EPA+DHA ranged from 0.84 g/d to 6 g/d; adherence ranged from 76 to 90 percent in the four studies that reported compliance. The duration of followup ranged from 1 to over 6 years. None of the studies found a significant effect on CHF hospitalizations comparing marine oil to placebo, with effect sizes ranging from 0.86 (95% CI 0.26 to 2.81) to 1.19 (95% CI 0.52 to 2.73).

### Observational Studies

Eight studies evaluated the associations between intake and biomarkers of n-3 FA and CHF (Appendix F, Congestive heart failure section; Figure 31).86, 100, 102, 112, 129, 132, 148, 153, 154 Definitions of CHF outcomes varied across studies, including incident CHF and CHF hospitalization. One study analyzed only people with a history of MI; the Cohort of Swedish Men also reported a subgroup analysis in people with either diabetes of a history of MI. The remaining analyses were conducted in generally healthy populations. The median followup duration across studies was 9.5 years (range of average followup 4 to 16 years). Studies found a mix of both significant associations between higher n-3 FA intake or biomarker levels and lower risk of CHF and lack of association.

Figure 31 n-3 FA associations with congestive heart failure: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, white squares = healthy males, black squares = healthy females

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids, PPFA = plasma polyunsaturated fatty acids.

This figure presents individual plots of the association of omega-3 fatty acid intake or biomarkers with congestive heart failure from longitudinal observational studies. The measures of omega-3 fatty acids include ALA intake grams per day, ALA plasma percent fatty acid, ALA plasma percent plasma phospholipid fatty acid, DHA plasma percent plasma phospholipid fatty acid, DPA plasma percent plasma phospholipid fatty acid, EPA+DHA intake grams per day, EPA+DHA+DPA plasma percent fatty acid, and EPA plasma percent plasma phospholipid fatty acid. These plots replicate results reported in Appendix F.

#### n-3 FA Intake

Six studies evaluated n-3 FA intake and CHF (Cardiovascular Health Study, Cohort of Swedish Men, Physician’s Health Study, Rotterdam, Swedish Mammography Study, Women’s Health Initiative). All but one analysis found no associations between n-3 FA intake and CHF.

The four studies assessing ALA intake (Cardiovascular Health Study, Physician’s Health Study, Swedish Mammography Study, Women’s Health Initiative) found no association with incident CHF or CHF hospitalization or death across 4 to 12 years of followup of healthy adults (Figure 31, plot #152).

Among the five studies evaluating EPA+DHA or EPA+DHA+DPA intake (Cohort of Swedish Men, Physician’s Health Study, Rotterdam, Swedish Mammography Study, Women’s Health Initiative), only the Swedish Mammography Study found an association between higher marine oil intake at baseline and CHF (hospitalization or death) in healthy women after 9 years of followup (Figure 31, plot #157). The Cohort of Swedish Men study, in contrast found no association after 7 years of followup, including in a subgroup analysis of men with a history of MI or diabetes at baseline.

By meta-analysis (Table 36), overall there is a just-significant association between higher marine oil intake and decreased risk of CHF across a median dosage range of 0.014 to 0.71 g/d (effect size per g/d = 0.76; 95% CI 0.58 to 1.00). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 0.5 g/d) consistently found a stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot closer to 1). This implies the possibility of a ceiling effect (where intake above a certain level adds no further benefit). However, given that the differences between lower and higher dose ES remained large across the range of testable dose thresholds, the actual ceiling dose threshold may be above the analyzable range (i.e., >0.5 g/d). At thresholds of 0.1 and 0.2 g/d, the difference in effect size at lower and higher doses were statistically significant (P values 0.04 and 0.03, respectively). But the most significant difference was found at the highest threshold tested, 0.5 g/d (P=0.02). The best fit curve was found with the lowest knot tested, 0.1 g/d.

Table 36 Meta-analysis results of observational studies of marine oil (EPA+DHA±DPA) intake and CHF2

N patients | Dose range, g/d | Knot | ES, overall | ES below knot | ES above knot | P^*^ | AIC | No. cohorts (crossing threshold)
184,491 | 0.014–0.71 | NA | 0.76 (0.58, 1.00) | | | | | 5
| | 0.1 | | 0.29 (0.12, 0.74) | 1.00 (0.67, 1.50) | 0.04 | 28.6 | 5
| | 0.2 | | 0.43 (0.26, 0.73) | 1.17 (0.70, 1.96) | 0.03 | 32.6 | 4
| | 0.3 | | 0.55 (0.38, 0.80) | 1.32 (0.61, 2.84) | 0.07 | 44.0 | 4
| | 0.4 | | 0.64 (0.47, 0.86) | 1.31 (0.37, 4.64) | 0.29 | 46.8 | 2
| | 0.5 | | 0.64 (0.49, 0.85) | 2.58 (0.93, 7.11) | 0.02 | 53.2 | 2

* ES below vs. above knot

Abbreviations: AIC = Akaike information criterion (estimation of fit of regression with spline), CHF = congestive heart failure, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, ES = effect size, NA = not applicable.

#### n-3 FA Biomarkers

Four studies conducted numerous analyses of n-3 FA biomarkers (Atherosclerosis Risk in Communities Study, Cardiovascular Health Study, Osaka Acute Coronary Insufficiency Study, Physician’s Health Study) in healthy adults (3 studies) and adults with a history of MI (Osaka Acute Coronary Insufficiency Study) with 4 or 14 years of followup.

One study (Cardiovascular Health Study) found lower incidence of CHF in adults ≥65 years old after 14 years of followup with higher plasma levels of total n-3 FA combined, but the association was not statistically significant (P=0.062).

Three studies analyzed plasma, cholesteryl ester, and phospholipid ALA (Atherosclerosis Risk in Communities Study, Cardiovascular Health Study, Physician’s Health Study) (Figure 31, plots #153 & 154). Only the Physicians Health study found an association of lower risk of CHF in men with higher plasma ALA levels after 4 years of followup; the Cardiovascular Health Study found no such association in adults ≥65 years at 14 years of followup and the Atherosclerosis Risk in Communities Study found no association with either cholesteryl ester or phospholipid ALA in younger adults (45–64 years old) also at 14 years of followup.

Three studies analyzed blood, plasma, cholesteryl ester, and phospholipid EPA (Atherosclerosis Risk in Communities Study, Cardiovascular Health Study, Osaka Acute Coronary Insufficiency Study). The studies had heterogeneous findings. The Cardiovascular Health Study found that higher plasma EPA levels were associated with lower risk of CHF in older adults (>65 y) with 14 years of followup (Figure 31, plot #159), in contrast to a lack of association for DHA (Figure 31, plot #155). The Osaka Acute Coronary Insufficiency Study also found a significant association between higher blood EPA levels and lower risk of CHF in adults with a history of MI (4 year followup), also in contrast with their finding for DHA (no association). The third study, the Atherosclerosis Risk in Communities Study, found no significant associations with either cholesteryl ester phospholipid DHA and CHF, with no difference in associations between men and women. These findings were also in contrast to their finding for DHA.

The same three studies analyzed the same DHA biomarkers, with heterogeneous findings. The Cardiovascular Health Study found no association with plasma DHA in healthy older adults (≥65 years, 14 year followup) (Figure 31, plot #155), in contrast with an association found for plasma EPA. The Osaka Acute Coronary Insufficiency Study also found no association with blood DHA in adults with a history of MI (4 year followup), in contrast to an association found for EPA. found a significant difference in association between men and women for both cholesteryl ester and phospholipid DHA.

Only the Cardiovascular Health Study evaluated plasma DPA (Figure 31, plot #156), in healthy older adults (≥65 years) with 14 years of followup. CHF risk was lower in participants with higher plasma DPA levels with near statistical significance (P=0.057).

Two studies analyzed biomarkers for combined marine oils. The Physicians Health Study found no association between plasma EPA+DHA+DPA and CHF risk in healthy men at 4 years (Figure 31, plot #158). The Atherosclerosis Risk in Communities Study also found no association with cholesteryl ester or phospholipid EPA+DHA+DPA and CHF in healthy men after 14 years. In women, no association was found with cholesteryl ester EPA+DHA+DPA, but higher levels of phospholipid EPA+DHA+DPA were associated with lower CHF risk.

#### Observational Study Subgroup Analyses

The Cardiovascular Health Study found no differences in associations between ALA plasma or intake levels and CHF in subgroups based on age, sex, diabetes, or fish consumption (Table 37).148

Table 37 Congestive heart failure: Subgroup analyses, observational studies

Study | Subgroups | n-3 FA | N Total | P difference | Difference^*^ | Favors
Cardiovascular Health Study148 | Fish consumption vs low or no fish consumption (<0.6 servings/week) | ALA (Plasma or Intake) | 4432 | NS
| Men vs Women | | | NS
| Age, continuous | | | NS
| Diabetes vs. no diabetes | | | NS
| Body mass index, continuous | | | NS
| Plasma linoleic acid, continuous | | | NS
Osaka Acute Coronary Insufficiency Study154 | Age <65 vs ≥65 years | DHA (Blood) | 671 | 0.051 | 0.52 vs. 3.00 | ≥65 y
| Male vs Female | | | 0.37
| Diabetes vs. no diabetes | | | 0.61
| Hypertension vs. no hypertension | | | 0.13
| Dyslipidemia vs. no dyslipidemia | | | 0.15
| LDL-c <100 vs ≥100 mg/dL | | | 0.068 | 3.48 vs. 0.88 | Low LDL-c
| HDL-c <40 vs ≥40 mg/dL | | | 0.096 | 4.50 vs. 1.17 | Low HDL-c
| Tg <150 vs. ≥ 150 mg/dL | | | 0.66
| eGFR <60 vs. ≥60 mL/min | | | 0.27
| Statin vs no statin | | | 0.003 | 0.74 vs. 6.65 | No statin
| ACEi/ARB vs. no ACEi/ARB | | | 0.39
| Beta blocker vs. no beta blocker | | | 0.37
| Age <65 vs ≥65 years | EPA (Blood) | 671 | 0.44
| Male vs Female | | | 0.008 | 5.82 vs. 0.69 | Male
| Diabetes vs. no diabetes | | | 0.98
| Hypertension vs. no hypertension | | | 0.84
| Dyslipidemia vs. no dyslipidemia | | | 0.14
| LDL-c <100 vs ≥100 mg/dL | | | 0.68
| HDL-c <40 vs ≥40 mg/dL | | | 0.034 | 15.7 vs. 1.44 | Low HDL-c
| Tg <150 vs. ≥ 150 mg/dL | | | 0.97
| eGFR <60 vs. ≥60 mL/min | | | 0.94
| Statin vs no statin | | | 0.048 | 1.45 vs. 6.40 | No statin
| ACEi/ARB vs. no ACEi/ARB | | | 0.17
| Beta blocker vs. no beta blocker | | | 0.27
Cohort of Swedish Men102 | History of DM or MI vs. healthy | EPA+DHA (Intake) | 5234 | NS
| Supplement use vs. no supplement | | | NS

* Hazard ratios refer to the association between low EPA and risk of CHF (i.e. higher HRs are better).

Abbreviations: ACEi = angiotensin-converting enzyme inhibitor, ALA = alphalinolenic acid, ARB = angiotensin receptor blocker, DHA = docosahexaenoic acid, DM = diabetes mellitus, eGFR = epidermal growth factor receptor, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MI = myocardial infarction, NS = not significant, Tg = triglycerides.

The Osaka Acute Coronary Insufficiency Study conducted multiple subgroup analyses for the associations between blood DHA, blood EPA, and CHF.154 For both biomarkers, no significant interaction between subgroups and associations were found for use of angiotensin receptor blocker drugs, use of beta blocker drugs, diabetes, dyslipidemia, hypertension, glomerular filtration function (threshold = 60 mL/min), or hypertriglyceridemia (threshold = 150 mg/dL). Statistically significant interactions were found for statin use. In participants taking statins, risk of CHF was not associated with blood DHA (HR=0.74) or EPA (HR=1.45) levels, in contrast with significant associations among participants not taking statins: DHA HR=6.65 (P interaction = 0.003); EPA HR=6.40 (P interaction = 0.048). Similarly for baseline HDL-c level, a significant interaction was found for blood EPA (P interaction = 0.034) and a nonsignificant interaction for blood DHA (P interaction = 0.096), such that significant associations were seen in participants with low HDL-c (<40 mg/dL), but not among those with higher HDL-c. Subgroup analyses by sex found a significant interaction (P interaction = 0.008) with blood EPA, but not blood DHA, such that in men there was a significant association between EPA and CHF risk (HR=3.48) but not among women (HR=0.88). Near-significant interactions were found for blood DHA and age (P interaction = 0.051, significant association found for those ≥65 years old) and LDL-c (P interaction = 0.068, significant association found for those with LDL-c <100 mg/dL) (Table 37). No interactions were found for blood EPA.

The Cohort of Swedish Men found no differences in associations of EPA+DHA intake and CHF between men with histories of diabetes or MI and healthy men, or between those who used marine oil supplements or not.102

## Hypertension, Incident

### Randomized Controlled Trials

No trial evaluated incident hypertension.

### Observational Studies

Two studies evaluated the associations between intake of multiple n-3 FA or erythrocyte FA and new-onset hypertension after about 13 or 20 years of followup in health adults (Appendix F, Hypertension section; Figure 32).118, 124 Statistically significant associations were found for younger, but not older, adults (with one exception). The Women’s Health Study found that overall total n-3 FA intake and erythrocyte levels were not significantly associated with risk of hypertension (Figure 32, plots #163 & 164). Among women 55 to 89 years old at baseline, there were also no significant associations with ALA, DHA, and EPA intake, and with erythrocyte total n-3 FA, ALA, DPA, and DHA levels, but higher erythrocyte EPA levels were associated with lower hypertension incidence. Among younger women, 39 to 54 years old at baseline, higher DHA intake and higher erythrocyte total n-3 FA, DPA, and DHA levels, but not ALA or EPA levels, were associated with lower hypertension risk. Similarly, the CARDIA study, all in 18 to 30 year old adults, with 20 year followup, higher EPA (Figure 32, plot #162), DHA (Figure 32, plot #160), and EPA+DHA+DPA (Figure 32, plot #161) intake were all significantly associated with lower hypertension incidence.

Figure 32 n-3 FA associations with incident hypertension: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. Studies that reported associations by continuous exposure (e.g., per g/d intake or per standard deviation) could not be graphed and are omitted. P values are the study-reported P value for the trend across quantiles. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults, black squares = healthy females

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure presents individual plots of the association of omega-3 fatty acid intake or biomarkers with incident hypertension from longitudinal observational studies. The measures of omega-3 fatty acids include DHA intake grams per day, EPA+DHA+DPA intake grams per day, EPA intake grams per day, total omega-3 fatty acid intake percent fatty acid, and total omega-3 fatty acid erythrocyte grams per day. These plots replicate results reported in Appendix F.

## Blood Pressure, Systolic and Diastolic

### Randomized Controlled Trials

Thirty-five RCTs provided data on effect of n-3 FA on systolic blood pressure (BP) (Table 38). Twenty-eight RCTs provided data on effect of n-3 FA on diastolic BP (Table 39). Only five of the trials reported BP to be a primary outcome (Carter 2012, Finnegan 2003, Harrison 2004, Lungershausen 1994, Vasquez 2014); however, Vasquez reported BP to be a secondary outcome in the ClinicalTrials.gov registry.53, 75, 80, 147, 174

Table 38 Systolic blood pressure: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int N | Int Baseline, mmHg | Ctrl N | Ctrl Baseline, mmHg | Net Chg, mmHg | Reported P value
Total n-3 FA vs. Placebo
Jones 2014 24829493 Canada | At risk | ALA + EPA+DHA | 3.48 DHA g/d+1.2 g/d ALA+0.12 EPA g/d+1.44 g/d DPA (suppl: CanolaDHA) | Placebo | 0 | 1 mo | nd | 130 | 120.62 | 130 | 120.62 | −1.9 (−44.7, 40.9) | nd
Kromhout 2010 20929341 Netherlands | CVD | ALA + EPA+DHA | 0.4 g/d EPA+DHA; 2 g/d ALA (Marine oil, plant oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1212 | 140.9 | 1236 | 141.9 | 2.3 (−0.1, 4.6) | NS
Marine oil vs. Placebo
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | Placebo | 0 | 2 mo | nd | 75 | 123.2 | 77 | 122.2 | −1.2 (−2.9, 0.5) | nd
| Healthy | DHA | 3.6 g/d (Ethyl ester) | Placebo | 0 | 2 mo | nd | 72 | 121.3 | 77 | 122.2 | −0.2 (−1.8, 1.4) | nd
Harrison 2004 15853118 UK | At risk | DHA+/− soy protein | 2 g/d (suppl: marine oil) | Placebo+/− soy protein | 0 | 1.25 mo | Food diaries, biomarker check | 101 | 130.9 | 112 | 134.7 | 3.8 (−1.7, 9.3) | nd
Carter 2012 22707560 U.S. | Healthy (normotensive) | EPA+DHA | 1.6 EPA g/d+1.1 DHA g/d (suppl: marine oil) | Placebo | 0 | 2 mo | Pill diary | 19 | 110 | 19 | 107 | −3 (−7, 1) | nd
| Healthy (pre-hypertensive) | EPA+DHA | 1.6 EPA g/d+1.1 DHA g/d (suppl: marine oil) | Placebo | 0 | | | 15 | 127 | 14 | 126 | 1 (−4.2, 6.2) | nd
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (suppl: marine oil, diet: marine oil margarine | Placebo | 0 | 4 mo | Pill count, plasma measurement | 31 | 118.4 | 30 | 123.2 | 0.2 (−5.6, 6.1) | nd
| Healthy | EPA+DHA | 0.8 g/d (suppl: marine oil) | Placebo | 0 | | | 30 | 119.6 | 30 | 123.2 | 2.8 (−4.1, 9.8) | nd
Grieger 2014 24454276 Australia | Healthy | EPA+DHA | 0.8 g/d (diet: fish) | Low n-3 FA diet (usual diet) | 0.017 g/d EPA and 0.004 g/d DHA (diet) | 2 mo | Food Records | 43 | 126 | 37 | 126 | −2.0 (−9.3, 5.3) | nd
Rasmussen 2006 16469978 Europe and Australia | Healthy | EPA+DHA | 2.4 g/d EPA+DHA | Placebo | 0 | 3 mo | nd | 80 | 122.6 | 82 | 122.3 | −0.4 (−2.6, 1.8) | 0.76
Sacks 1994 8021472 U.S. | Healthy | EPA+DHA | 1.44 EPA g/d+0.96 DHA g/d+0.6 DPA g/d (suppl: marine oil) | Placebo | 0 | 6 mo | FA measurement and pill count | 175 | 122.9 | 175 | 122.6 | −0.1 (−1.5, 1.3) | NS
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl: marine oil) EPA:DHA: 1.51 | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 119.1 | 71 | 122.6 | −0.3 (−4.3, 3.7) | nd
| | EPA+DHA | 0.9 g/d (suppl: marine oil) EPA:DHA : 1.51 | Placebo | 0 | 1 y | Pill Count, Plasma Check | 79 | 123.5 | 71 | 122.6 | −0.8 (−4.8, 3.2) | nd
| | EPA+DHA | 0.45 g/d (suppl: marine oil) EPA:DHA : 1.51 | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 122.6 | 71 | 122.6 | 0 (−4, 4) | nd
Tardivo 2015 25394692 Brazil | Healthy | EPA+DHA | 0.9 g/d [E:D 3:2] | Placebo | 0 | 6 mo | Pill count | 44 | 138.3 | 43 | 134.5 | −13.9 (−20.9, −6.9) | nd
Vazquez 2014 24462043 Spain | Healthy | EPA+DHA | 0.64 g/d [E:D 1:3] | Placebo | 0 | 2 mo | Assessed by trained dieticians at each visit | 273 | 140.5 | 273 | 140.5 | −0.28 (−2.6, 2.1) | 0.787
Pase 2015 25565485 Australia | Healthy | EPA+DHA±DPA | 480 mg/d EPA + 480 mg/d DHA [E:D 1:1] | Placebo | 0 | 4 mo | nd | 38 | 117 | 32 | 109.8 | −6.9 (−0.2, 14.0) | nd
Bosch 2012 22686415 Canada | At risk | EPA+DHA | EPA+DHA 0.84 g/d (suppl: marine oil) | Placebo | 0 | 6 y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 6281 | 145.6 | 6255 | 146.0 | 0.1 (−0.6, 0.9) | 0.75
Tierney 2011 20938439 Northern Europe | At risk | EPA+DHA | EPA 0.26 g/d, DHA 0.19 g/d (suppl) [E:D 1.5] | Placebo | 0 | 3 mo | Pill Count and plasma FA | 100 | 137.73 | 106 | 139.53 | 0.1 (−4, 4.2) | NS
Derosa 2009 19397392 Italy | At risk | EPA+DHA | 0.9 g/d EPA+1.5 g/d DHA (suppl: marine oil) E:D : 0.6 | Placebo | 0 | 6 mo | Pill Count | 168 | 128.4 | 165 | 129.6 | 0 (−1.4, 1.4) | nd
Ebrahimi 2009 19593941 Iran | At risk | EPA+DHA | 0.18 g/d EPA+0.12 g/d DHA (suppl: marine oil) | Placebo | 0 | 6 mo | nd | 47 | 130.7 | 42 | 129.6 | −5.3 (−13.4, 2.8) | nd
Einvik 2010 20389249 Norway | At risk | EPA+DHA (no diet intervention) | 2.4 g n-3 FA (1.17 g EPA and 0.84 g DHA) (Suppl: marine oil), E:D: 2:1 | Placebo (no diet intervention) | 0 | 3 y | Pharmacy records of remaining capsules, and measurements of serum n-3 FA | 70 | 150 | 68 | 148 | −2 (−8.7, 4.7) | nd
| | EPA+DHA (diet intervention) | 2.4 g n-3 FFA (1.17 g EPA and 0.84 g DHA) (Suppl: marine oil), E:D: 2:1 | Placebo (diet intervention) | 0 | | | 69 | 149 | 71 | 149 | −1 (−7.7, 5.7) | nd
Holman 2009 19002433 UK | At risk | EPA+DHA (+/− atorvastatin) | EPA+DHA 1.68 g/d (suppl: marine oil) E:D : 1.2 | Placebo (+/− atorvastatin) | 0 | 4 mo | Pill count | 371 | 137 | 361 | 139 | 0.39 (−1.88, 2.66) | 0.82
Lungershausen 1994 7852747 Australia | At risk | EPA+DHA | 1.9 g/d EPA, 1.5 g/d DHA (suppl) E:D : 1.27 | Placebo | 0 | 1.5 mo | Interview and Pill Count | 42 | 132 | 42 | 132 | −3.1 (−8.3, 2.1) | 0.012
Nodari 2011 21215550 Italy | At risk | EPA+DHA | 4.25 – 4.41 g/d EPA+DHA daily for the first month followed by 1.7 – 1.764 g/d (suppl: marine oil) EPA:DHA : 0.6 | Placebo | 0 | 1 y | nd | 67 | 119 | 66 | 120 | 3 (−0.4, 6.4) | 0.015
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | EPA+DHA <0.85 g/d (suppl: marine oil) (E:D 1] | Placebo | 0 | 5 y | Patient Self–Report | 6244 | 140.3 | 6269 | 140.1 | 0.2 (−0.4, 0.7) | 0.57
Soares 2014 24652053 Brazil | At risk | EPA+DHA (and dietary intervention) | 3 g/d (suppl: marine oil) | Placebo and dietary intervention | 0 | 3 mo | nd | 20 | 130.2 | 18 | 134.4 | 0.6 (−1.5, 2.7) | 0.702 (overall)
| | EPA+DHA (and dietary intervention+exercise) | 3 g/d (suppl: marine oil) | Placebo and dietary intervention and exercise | 0 | | | 17 | 131.6 | 15 | 131.1 | 3.8 (1.2, 6.4) | 0.702 (overall)
Jones 2014 24829493 Canada | At risk | EPA+DHA+ALA (Canola DHA) | 3.48 DHA g/d+1.2 g/d ALA+0.12 EPA g/d+1.44 g/d DPA (suppl: CanolaDHA) | ALA (Canola Oleic) | 1.38 g/d | 1 mo | nd | 130 | 120.6 | 130 | 120.6 | −1.2 (−44, 41.7) | nd
Yokoyama 2007 17398308 Japan | At risk (no previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 8841 | 135 | 8862 | 135 | 0 (−0.9, 0.9) | 0.575
Burr 1989 2571009 UK | CVD | EPA+DHA | 0.357 EPA g/d+nd DPA (suppl: marine oil, diet: fish) | No intervention | 0 | 2 y | Dietary Questionnaire | 1015 | 129.7 | 1018 | 130.1 | 0.4 (−1.3, 2.1) | nd
Galan 2010 21115589 France | CVD | EPA+DHA (+/− B vitamin) | 0.6 g/d (suppl: marine oil) [E:D 2:1] | Placebo (+/− B vitamin | 0 | 4.7 y | Self–Report | 1253 | 134 | 1248 | 133 | −0.06 (−0.9, 0.8) | nd
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | EPA+DHA 0.75 – 0.882 g/d (Ethyl esters) (E:D : 0.833] | Placebo | 0 | 3.9 y | Pill count | 3494 | 126 | 3481 | 126 | nd | 0.47
Sacks 1995 7759696 U.S. | CVD | EPA+DHA | 2.88 g/d EPA and 3.12 g/d DHA (suppl: marine oil) (E:D 0.923) | Placebo | 0 | 2.4 y | Pill Count | 31 | 126 | 28 | 133 | −1.0 (−14, 12.0) | nd
von Schacky 1999 10189324 Canada | CVD | EPA+DHA | EPA+DHA 3.3 g/d for 3 months then 1.65 g/d for 21 months (suppl: marine oil) | Placebo | 0 | 1 y | Interrogation, Pill Count, and analysis of FA | 112 | 132.0 | 111 | 129.6 | −0.1 (−4.9, 4.7) | NS
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1192 | 142.3 | 1236 | 141.9 | 1.7 (−0.6, 3.9) | NS
| | EPA+DHA (+ALA) | 0.4 g/d (Marine oil) [E:D 3:2] | (ALA) | 0 | | | 1212 | 140.9 | 1197 | 141.4 | 0.2 (−2.0, 2.5) | nd
Yokoyama 2007 17398308 Japan | CVD | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 485 | 139 | 457 | 139 | 0 (−2.6, 2.6) | 0.607
EPA+DHA vs. EPA+DHA (doses)
Pase 2015 25565485 Australia | Healthy | EPA+DHA±DPA + Multivitamin | 480 mg/d EPA + 480 mg/d DHA [E:D 1:1] | EPA+DHA±DPA + Multivitamin | 280 mg/d EPA + 280 mg/d DHA | 4 mo | nd | 36 | 112.8 | 38 | 116.5 | −1 (−9.0, 7.0) | nd
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d | EPA+DHA | 0.8 g/d | 4 mo | Pill count, plasma measurement | 31 | 118.4 | 30 | 119.6 | −2.6 (−7.9, 2.7) | nd
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl: marine oil) EPA:DHA : 1.51 | EPA+DHA | 0.9 g/d (suppl: marine oil) | 1 y | Pill Count, Plasma Check | 80 | 119.1 | 79 | 123.5 | 0.5 (−3.5, 4.5) | nd
| | EPA+DHA | 1.8 g/d (suppl: marine oil) EPA:DHA : 1.51 | EPA+DHA | 0.45 g/d (suppl: marine oil) | 1 y | Pill Count, Plasma Check | 80 | 119.1 | 80 | 122.6 | −0.3 (−4.3, 3.7) | nd
| | EPA+DHA | 0.9 g/d (suppl: marine oil) | EPA+DHA | 0.45 g/d (suppl: marine oil) | 1 y | Pill Count, Plasma Check | 79 | 123.5 | 80 | 122.6 | −0.8 (−4.8, 3.2) | nd
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 1 y | nd | 171 | nd | 165 | nd | 1.6 (nd) | nd
Marine oil vs. marine oil (miscellaneous)
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | DHA | 3.6 g/d (Ethyl ester) | 2 mo | nd | 77 | 122.2 | 72 | 121.3 | −1.0 (−2.8, 0.8) | nd
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 171 | nd | 167 | nd | 2.6 (nd) | nd
| | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 165 | nd | 167 | nd | 1.0 (nd) | nd
ALA vs. Placebo
Finnegan 2003 12663273 UK | Healthy | ALA | 4.5 g/d (rapeseed oil margarine) | Placebo | 0 | 4 mo | Return of margarine pots (>90%) | 30 | 118.2 | 30 | 123.2 | 4.5 (−0.6, 9.6) | nd
Rodriguez-Leyva 2013 24126178 Canada | At risk | ALA | 5.9 g/d (flaxseed) | Placebo | 0 | 1 y | Plasma ALA and enterolignan levels | 45 | 143.3 | 41 | 142.4 | −7.3 (−15.4, 0.80) | nd
Baxheinrich 2012 22894911 Germany | At risk | ALA | 3.46 g/d (suppl: plant oil) | Placebo | 0 | 6 mo | Dietary records | 40 | 142.4 | 41 | 140.1 | −1.8 (−8.3, 4.7) | 0.697
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | Placebo | 0 | 1 mo | nd | 130 | 120.6 | 130 | 120.6 | −1.1 (−43.9, 41.8) | nd
| | ALA | 1.38 g/d (canola) | Placebo | 0 | | | 130 | 120.6 | 130 | 120.6 | −1.0 (−43.8, 41.8) | nd
Kromhout 2010 20929341 Netherlands | CVD | ALA | 2 g/d (plant oil) | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1197 | 141.4 | 1236 | 141.9 | 2.1 (−0.2, 4.3) | NS
| | ALA (+EPA+DHA) | 2 g/d (plant oil) | (EPA+DHA) | 0 | | | 1212 | 140.9 | 1192 | 142.3 | 0.6 (−1.6, 2.9) | nd
ALA vs. ALA (doses)
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | ALA | 1.38 g/d (canola) | 1 mo | nd | 130 | 120.6 | 130 | 120.6 | −0.1 (−42.9, 42.8) | nd
Marine oil vs. ALA
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d | ALA | 4.5 g/d (rapeseed oil margarine) | | | 31 | 118.4 | 30 | 118.2 | −4.3 (−9.4, 0.9) | nd
| | EPA+DHA | 0.8 g/d | ALA | 4.5 g/d (rapeseed oil margarine) | | | 30 | 119.6 | 30 | 118.2 | −1.7 (−6.1, 2.8) | nd
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | ALA | 2 g/d (plant oil) | 40 mo | Audit of unused margarine tubs returned | 1192 | 142.3 | 1197 | 141.4 | −0.4 (−2.6, 1.8) | nd

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FFQ = food frequency questionnaire, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, NS = not significant, PMID = PubMed Identification number, RCT = randomized controlled trial.

Table 39 Diastolic blood pressure: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int N | Int Baseline, mmHg | Ctrl N | Ctrl Baseline, mmHg | Net Chg, mmHg | Reported P value
Total n-3 FA vs. Placebo
Jones 2014 24829493 Canada | At risk | ALA + EPA+DHA | 3.48 DHA g/d+1.2 g/d ALA+0.12 EPA g/d+1.44 g/d DPA (suppl: CanolaDHA) | Placebo | 0 | 1 mo | nd | 130 | 77.0 | 130 | 77.0 | −2.5 (−31.3, 26.3) | nd
Kromhout 2010 20929341 Netherlands | CVD | ALA + EPA+DHA | 0.4 g/d EPA+DHA; 2 g/d ALA (Marine oil, plant oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1212 | nd | 1236 | nd | 0.5 (−0.7, 1.7) | NS
Marine oil vs. Placebo
Pase 2015 25565485 Australia | Healthy | EPA+DHA±DPA | 480 mg/d EPA + 480 mg/d DHA [E:D 1:1] | Placebo | 0 | 4 mo | nd | 38 | 78.3 | 36 | 74.1 | −3.5 (−8.2, 1.2) | nd
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | Placebo | 0 | 2 mo | nd | 75 | 78.1 | 77 | 76.9 | −0.6 (−1.9, 0.7) | nd
| Healthy | DHA | 3.6 g/d (Ethyl ester) | Placebo | 0 | 2 mo | nd | 72 | 76.1 | 77 | 76.9 | −0.4 (−1.8, 1.0) | nd
Carter 2012 22707560 U.S. | Healthy (normotensive) | EPA+DHA | 1.6 EPA g/d+1.1 DHA g/d (suppl: marine oil) | Placebo | 0 | 2 mo | Pill diary | 19 | 66 | 19 | 65 | −1.0 (−3.6, 1.6) | nd
| Healthy (pre-hypertensive) | EPA+DHA | 1.6 EPA g/d+1.1 DHA g/d (suppl: marine oil) | Placebo | 0 | | | 15 | 68 | 14 | 74 | 0 (−5.2, 5.2) | nd
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (suppl: marine oil, diet: marine oil margarine | Placebo | 0 | 4 mo | Pill count, plasma measurement | 31 | 74.8 | 30 | 76.0 | −0.1 (−5, 4.7) | nd
| Healthy | EPA+DHA | 0.8 g/d (suppl: marine oil) | Placebo | 0 | | | 30 | 74.6 | 30 | 76.0 | 1.9 (−3.7, 7.6) | nd
Grieger 2014 24454276 Australia | Healthy | EPA+DHA | 0.8 g/d (diet: fish) | Low n-3 FA diet (usual diet) | 0.017 g/d EPA and 0.004 g/d DHA (diet) | 2 mo | Food Records | 43 | 69 | 37 | 67 | 0 (−3.9, 3.9) | nd
Rasmussen 2006 16469978 Europe and Australia | Healthy | EPA+DHA | 2.4 g/d EPA+DHA | Placebo | 0 | 3 mo | nd | 80 | 76 | 82 | 77 | −0.6 (−2.8, 0.8) | nd
Sacks 1994 8021472 U.S. | Healthy | EPA+DHA | 1.44 EPA g/d+0.96 DHA g/d+0.6 DPA g/d (suppl: marine oil) | Placebo | 0 | 6 mo | FA measurement | 175 | 81.0 | 175 | 81.1 | −0.4 (−1.5, 0.6) | NS
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl: marine oil) EPA:DHA : 1.51 | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 71.8 | 71 | 74.1 | 0.6 (−1.4, 2.6) | nd
| Healthy | EPA+DHA | 0.9 g/d (suppl: marine oil) EPA:DHA : 1.51 | Placebo | 0 | 1 y | Pill Count, Plasma Check | 79 | 73.9 | 71 | 74.1 | 0.6 (−1.5, 2.7) | nd
| Healthy | EPA+DHA | 0.45 g/d (suppl: marine oil) EPA:DHA : 1.51 | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 71.2 | 71 | 74.1 | 1.2 (−0.9, 3.3) | nd
Tardivo 2015 25394692 Brazil | Healthy | EPA+DHA | 0.9 g/d [E:D 3:2] | Placebo | 0 | 6 mo | Pill count | 44 | 86.2 | 43 | 85.3 | −5.7 (−8.5, −2.9) | nd
Vazquez 2014 24462043 Spain | Healthy | EPA+DHA | 0.64 g/d [E:D 1:3] | Placebo | 0 | 2 mo | Assessed by trained dieticians at each visit | 273 | 83.9 | 273 | 83.9 | −1.32 (−2.5, −0.1) | 0.014
Bosch 2012 22686415 Canada | At risk | EPA+DHA | EPA+DHA 0.84 g/d (suppl: marine oil) | Placebo | 0 | 6 y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 6281 | 84.1 | 6255 | 84.2 | 0.1 (−0.3, 0.5) | 0.91
Tierney 2011 20938439 Northern Europe | At risk | EPA+DHA | EPA 0.26 g/d, DHA 0.19 g/d (suppl) [E:D 1.5] | Placebo | 0 | 3 mo | Pill Count and plasma FA | 100 | 85.5 | 106 | 85.52 | 0.7 (−1.7, 3.1) | NS
Derosa 2009 19397392 Italy | At risk | EPA+DHA | 0.9 g/d EPA+1.5 g/d DHA (suppl: marine oil) E:D : 0.6 | Placebo | 0 | 6 mo | Pill Count | 168 | 80.6 | 165 | 81.4 | 0.2 (−1.3, 1.7) | nd
Ebrahimi 2009 19593941 Iran | At risk | EPA+DHA | 0.18 g/d EPA+0.12 g/d DHA (suppl: marine oil) | Placebo | 0 | 6 mo | nd | 47 | 81.7 | 42 | 78.3 | −4.5 (−9, 0.03) | nd
Einvik 2010 20389249 Norway | At risk | EPA+DHA (no diet intervention) | 2.4 g n-3 FA (1.17 g EPA and 0.84 g DHA) (Suppl: marine oil), E:D: 2:1 | Placebo (no diet intervention) | 0 | 3 y | Pharmacy records of remaining capsules, and measurements of serum n-3 FA | 70 | 83 | 68 | 83 | 0 (−3.9, 3.9) | nd
| At risk | EPA+DHA (diet intervention) | 2.4 g n-3 FA (1.17 g EPA and 0.84 g DHA) (Suppl: marine oil), E:D: 2:1 | Placebo (diet intervention) | 0 | | | 69 | 85 | 71 | 83 | −1.0 (−5.0, 3.0) | nd
Harrison 2004 15853118 UK | At risk | DHA +/− soy protein | 2 g/d (suppl: marine oil) | Placebo +/− soy protein | 0 | 1.25 mo | Food diaries, biomarker check | 101 | 81.1 | 112 | 81.8 | −1.0 (−4.5, 2.4) | nd
Holman 2009 19002433 UK | At risk | EPA+DHA (+/− atorvastatin) | EPA+DHA 1.68 g/d (suppl: marine oil) E:D : 1.2 | Placebo (+/− atorvastatin) | 0 | 4 mo | Pill count | 371 | 77 | 361 | 78 | 0.6 (−1.09, 2.29) | 0.34
Jones 2014 24829493 Canada | At risk | ALA + EPA+DHA (Canola DHA) | 3.48 DHA g/d+1.2 g/d ALA+0.12 EPA g/d+1.44 g/d DPA (suppl: CanolaDHA) | ALA (Canola Oleic) | 1.38 g/d | 1 mo | nd | 130 | 77.0 | 130 | 77.0 | −2.2 (−30.9, 26.6) | nd
Lungershausen 1994 7852747 Australia | At risk | EPA+DHA | 1.9 g/d EPA, 1.5 g/d DHA (suppl) E:D : 1.27 | Placebo | 0 | 1.5 mo | Interview and Pill Count | 42 | 76.2 | 42 | 76.2 | −1.8 (−4.8, 1.2) | 0.006
Nodari 2011 21215550 Italy | At risk | EPA+DHA | 4.25 – 4.41 g/d EPA+DHA daily for the first month followed by 1.7 – 1.764 g/d (suppl: marine oil) EPA:DHA : 0.6 | Placebo | 0 | 1 y | nd | 67 | 76 | 66 | 76 | −1.0 (−2.6, 0.6) | 0.015
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | EPA+DHA <0.85 g/d (suppl: marine oil) (E:D 1] | Placebo | 0 | 5 y | Patient Self–Report | 6239 | 82.9 | 6266 | 82.5 | −0.26 (−25.2, 24.7) | 0.57
Yokoyama 2007 17398308 Japan | At risk (no previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 8841 | 78 | 8862 | 78 | 0 (−0.4, 0.4) | 0.986
Burr 1989 2571009 UK | CVD | EPA+DHA | 0.357 EPA g/d+nd DPA (suppl: marine oil, diet: fish) | No intervention | 0 | 2 y | Dietary Questionnaire | 1015 | 79.3 | 1018 | 80.2 | 0.2 (−0.9, 1.3) | nd
Galan 2010 21115589 France | CVD | EPA+DHA (+/− B vitamin) | 0.6 g/d (suppl: marine oil) [E:D 2:1] | Placebo (+/− B vitamin | 0 | 4.7 y | Self–Report | 1253 | 84 | 1248 | 83 | 0.06 (−0.5, 0.6) | nd
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1192 | nd | 1236 | nd | −0.4 (−1.6, 0.7) | NS
| CVD | EPA+DHA (+ALA) | 0.4 g/d (Marine oil) [E:D 3:2] | ALA | 0 | | | 1212 | nd | 1197 | nd | −0.5 (−1.6, 0.7) | nd
Sacks 1995 7759696 U.S. | CVD | EPA+DHA | 2.88 g/d EPA and 3.12 g/d DHA (suppl: marine oil) (E:D 0.923) | Placebo | 0 | 2.4 y | Pill Count | 31 | 76 | 28 | 77 | 1.0(−4.6, 6.6) | nd
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | EPA+DHA 0.75 – 0.882 g/d (Ethyl esters) (E:D : 0.833] | Placebo | 0 | 3.9 y | Pill count | 3494 | 77 | 3481 | 77 | nd | 0.43
von Schacky 1999 10189324 Canada | CVD | EPA+DHA | EPA+DHA 3.3 g/d for 3 months then 1.65 g/d for 21 months (suppl: marine oil) | Placebo | 0 | 1 y | Interrogation, Pill Count, and analysis of FA | 112 | 80.7 | 111 | 79.8 | 0.2 (−2.8, 3.2) | NS
Yokoyama 2007 17398308 Japan | CVD | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 485 | 80 | 457 | 79 | −1 (−2.6, 0.6) | 0.538
EPA+DHA vs. EPA+DHA (doses)
Pase 2015 25565485 Australia | Healthy | EPA+DHA±DPA + Multivitamin | 480 mg/d EPA + 480 mg/d DHA [E:D 1:1] | EPA+DHA±DPA + Multivitamin | 280 mg/d EPA + 280 mg/d DHA | 4 mo | nd | 36 | 76.5 | 38 | 78.2 | −1.5 (−7.0, 4.0) | nd
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d | EPA+DHA | 0.8 g/d | 4 mo | Pill count, plasma measurement | 31 | 74.8 | 30 | 74.6 | −2.1 (−6.6, 2.4) | nd
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl: marine oil) EPA:DHA : 1.51 | EPA+DHA | 0.9 g/d (suppl: marine oil) | 1 y | Pill Count, Plasma Check | 80 | 71.8 | 79 | 73.9 | 0 (−2.0, 2.0) | nd
| | EPA+DHA | 1.8 g/d (suppl: marine oil) EPA:DHA : 1.51 | EPA+DHA | 0.45 g/d (suppl: marine oil) | 1 y | Pill Count, Plasma Check | 80 | 71.8 | 80 | 71.2 | −0.6 (−2.5, 1.3) | nd
| | EPA+DHA | 0.9 g/d (suppl: marine oil) | EPA+DHA | 0.45 g/d (suppl: marine oil) | 1 y | Pill Count, Plasma Check | 79 | 73.9 | 80 | 71.2 | −0.6 (−2.7, 1.5) | nd
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 1 y | nd | 171 | nd | 165 | nd | 0.4 (nd) | nd
Marine oil vs. marine oil (miscellaneous)
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | DHA | 3.6 g/d (Ethyl ester) | 2 mo | nd | 77 | 78.1 | 72 | 76.1 | −0.2 (−1.6, 1.2) | nd
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 171 | nd | 167 | nd | −0.8 (nd) | nd
| | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | | | 165 | nd | 167 | nd | −1.2 (nd) | nd
ALA vs. Placebo
Finnegan 2003 12663273 UK | Healthy | ALA | 4.5 g/d (rapeseed oil margarine) | Placebo | 0 | 4 mo | Return of margarine pots (>90%) | 30 | 76.0 | 30 | 76.0 | 0.6 (−3.5, 4.7) | nd
Rodriguez-Leyva 2013 24126178 Canada | At risk | ALA | 5.9 g/d (flaxseed) | Placebo | 0 | 6 mo | Plasma ALA and enterolignan levels | 45 | 77 | 41 | 79 | −2.1 (−7.2, 3.0) | nd
Baxheinrich 2012 22894911 Germany | At risk | ALA | 3.46 g/d (suppl: plant oil) | Placebo | 0 | 6 mo | Dietary records | 40 | 91.8 | 41 | 90.2 | −3.9 (−8.1, 0.3) | 0.026
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | Placebo | 0 | 1 mo | nd | 130 | 77.0 | 130 | 77.0 | 0.1 (−28.8, 28.8) | nd
| | ALA | 1.38 g/d (canola) | Placebo | 0 | | | 130 | 77.04 | 130 | 77.04 | −0.3 (−29.1, 28.5) | nd
Kromhout 2010 20929341 Netherlands | CVD | ALA | 2 g/d (plant oil) | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1197 | nd | 1236 | nd | 1.0 (−0.2, 2.1) | NS
| | ALA (+EPA+DHA) | 2 g/d (plant oil) | (EPA+DHA) | 0 | | | 1212 | nd | 1192 | nd | 0.9 (−0.3, 2.1) | nd
ALA vs. ALA (doses)
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | ALA | 1.38 g/d (canola) | 1 mo | nd | 130 | 77.04 | 130 | 77.04 | 0.3 (−28.5, 29.1) | nd
Marine oil vs. ALA
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d | ALA | 4.5 g/d (rapeseed oil margarine) | | | 31 | 74.8 | 30 | 76.0 | −0.7 (−5.3, 3.8) | nd
| | EPA+DHA | 0.8 g/d | ALA | 4.5 g/d (rapeseed oil margarine) | | | 30 | 74.6 | 30 | 76.0 | 1.3 (−2.4, 5.1) | nd
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | ALA | 2 g/d (plant oil) | 40 mo | Audit of unused margarine tubs returned | 1192 | nd | 1197 | nd | −1.4 (−2.5, −0.2) | nd

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, ND = no data, NS = not significant, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### Total n-3 FA Versus Placebo

Two RCTs evaluated supplementation with combined ALA and marine oil (1.2 or 2 g ALA, and 3.6 or 0.4 g EPA+DHA) versus placebo in people with at least one of several risk factors for CVD in one trial180 or with CVD in the second trial.119 In the at-risk population, at 1 month followup, no differences in systolic or diastolic BP were seen, and the confidence intervals were wide (systolic net change = −1.9 mmHg; 95% CI −44.7 to 40.9; diastolic net change = −2.5 mmHg; 95% CI −31.3 to 26.3). In the CVD population, the study found nonsignificant increases in systolic (2.3 mmHg; 95% CI −0.1 to 4.6) and diastolic (0.5 mmHg; 95% CI −0.7 to 1.7) BPs.

#### Marine Oil Versus Placebo

Twenty-nine RCTs compared marine oil versus placebo (or control) and reported on changes in systolic BP in populations of healthy people, those at risk for CVD primarily related to a diagnosis of hypertension, and those with existing CVD (Table 38, Figure 33).48, 51, 53, 55, 61, 62, 75, 80, 85, 90, 96, 99, 103, 105, 115, 119, 120, 123, 133, 136, 146, 147, 160, 173, 174, 179, 180, 189, 190 Across the 29 trials, no significant effect was found on systolic BP: summary net change = 0.10 mmHg (95% CI −0.20 to 0.40).

Figure 33 Systolic blood pressure: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, n-3 FA = omega-3 fatty acids

This figure presents meta-analysis results for systolic blood pressure in randomized controls that looked at comparisons between marine oil omega-3 fatty acid intake versus a placebo. The meta-analysis was divided into healthy (ten studies), at risk (fifteen cohorts) and cardiovascular disease (seven cohorts) populations. Subgroup meta-analysis of the healthy, at risk and cardiovascular disease populations yielded nonsignificant summaries of −0.63 (−1.45, 0.18), 0.22 (−0.14, 0.59) and 0.17 (−0.48, 0.82), respectively. The overall summary 0.10 (−0.48, 0.82) was also nonsignificant. Net differences across studies were mostly heterogeneous.

All but one of these trials also reported diastolic BP.179 Across the 28 trials (Table 39, Figure 34), no significant effect was found on diastolic BP: summary net change = −0.19 mmHg (95% CI −0.43 to 0.05).

Figure 34 Diastolic blood pressure: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DBP = diastolic blood pressure, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, n-3 FA = omega-3 fatty acids, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure presents meta-analysis results for diastolic blood pressure in randomized controls that looked at comparisons between marine oil omega-3 fatty acid intake versus a placebo. The meta-analysis was divided into healthy (ten studies), at risk (thirteen cohorts) and cardiovascular disease (seven cohorts) populations. Subgroup meta-analysis of the healthy population yielded significant summaries, at risk and cardiovascular disease populations yielded nonsignificant summaries of −0.97 (−1.82, −0.13), 0.01 (−0.26, 0.27) and −0.11 (−0.52, 0.30), respectively. The overall summary −0.19 (−0.43, 0.05) was nonsignificant. Net differences across studies were mostly homogeneous.

##### Healthy Population

Ten RCTs contributed to a pooled analysis of marine oils (EPA+DHA) against placebo for systolic BP, comprising data from 2,156 healthy individuals with mean baseline systolic BP ranging between 107 to 140.5 mmHg.51, 61, 75, 85, 136, 147, 173, 174, 189, 190 One study compared both EPA (3.8 g/d) and DHA (3.6 g/d) ethyl esters, separately, to placebo;61 all other evaluated supplements with both EPA+DHA. Marine oil dosage ranged from 0.64 to 3.8 g/d, and follow-up duration from 2 months to 1 year. Five studies reported their compliance verification methods (including self-report, food records, pill count, and plasma measurement). All RCTs found no significant effect of EPA+DHA on systolic BP; net systolic BP varied between −3.0 and 1.2 mmHg. The pooled effect size was a nonsignificant −0.63 mmHg (95% CI −1.45 to 0.18).

Ten RCTs contributed to a pooled analysis of marine oils (EPA+DHA) against placebo for diastolic BP, comprising data from 2,240 healthy individuals with mean baseline diastolic BP ranging between 65 to 85.3 mmHg.51, 61, 75, 85, 136, 147, 173, 174, 189, 190 RCTs found no significant effect of EPA+DHA on diastolic BP; net diastolic BP varied between −5.7 and 1.9 mmHg. The pooled effect size was a nonsignificant −0.97 mmHg (95% CI −1.82 to −0.13).

##### At-Risk-for-CVD Population

Thirteen RCTs contributed to a pooled analysis for systolic BP of marine oils (EPA+DHA) against placebo in those at risk for CVD, comprising data from 45,150 individuals, primarily due to hypertension, with mean baseline systolic BP ranging between 120 and 149 mmHg.53, 80, 90, 99, 103, 105, 115, 120, 133, 146, 160, 179, 180 One study compared DHA (2 g/d) to placebo;80 the rest evaluated supplements with EPA+DHA. Dosage ranged from 0.30 to 6 g/d, and follow-up duration from 1 month to 6 years. Eight RCTs reported their compliance verification methods (including self-report, pill count, and plasma measurements). Across trials, the net change in systolic BP varied from −5.3 and 3.8 mmHg, all of which were nonsignificant. The pooled effect size was a nonsignificant 0.22 mmHg (95% CI −0.14 to 0.59).

Twelve RCTs contributed to a pooled analysis for diastolic BP of marine oils (EPA+DHA) against placebo in those at risk for CVD, comprising data from 45,072 individuals, primarily due to hypertension, with mean baseline diastolic BP ranging between 76 and 85.5 mmHg.53, 80, 90, 99, 103, 105, 115, 120, 133, 146, 160, 180 Across trials, the net change in diastolic BP varied from −4.5 and 0.7 mmHg, all of which were nonsignificant. The pooled effect size was a nonsignificant 0.01 mmHg (95% CI −0.26 to 0.27).

##### CVD Population

Six RCTs contributed to a pooled analysis for systolic BP of marine oils (EPA+DHA) against placebo, comprising data from 11,791 individuals with CVD (mean baseline systolic BP 126 to 133 mmHg).48, 51, 62, 90, 119, 123 A sixth trial reported only that no significant effect on BP was found.96 Dosage ranged from 0.36 to 6 g/d, and follow-up durations from 1 and 4.7 years. They reported a variety of compliance verification methods (self-report, dietary questionnaire, pill count/audit, and plasma measurements). None of the RCTs found a significant effect of EPA+DHA on systolic BP, with net change ranging from −1 to 0.4 mmHg. The pooled effect size was a nonsignificant 0.17 mmHg (95% CI −0.48 to 0.82).

Six RCTs contributed to a pooled analysis for diastolic BP of marine oils (EPA+DHA) against placebo (mean baseline diastolic BP 77 to 83 mmHg).48, 51, 62, 90, 119, 123 None of the RCTs found a significant effect of EPA+DHA on diastolic BP, with net change ranging from −0.5 to 1.0 mmHg. The pooled effect size was a nonsignificant −0.11 mmHg (95% CI −0.52 to 0.30).

##### RCT Subgroup Analyses

Carter 2012 found no differences in effect on BP between two subpopulations of those with prehypertension or normal BP.147

By meta-regression, no differences in effect were found based on population (at risk P=0.99 systolic, P=0.24 diastolic; CVD P=0.99 systolic, P=0.97 diastolic), n-3 FA dose (P=0.56 systolic, P=0.42 diastolic), baseline systolic BP (P=0.91 systolic) or diastolic BP (P=0.21 diastolic), or followup duration (P=0.38 systolic, P=0.37 diastolic).

#### ALA Versus Placebo

Five trials compared ALA supplementation to placebo, one in a healthy population,75 three in at risk populations,152, 167, 180 and one in a population with CVD (Tables 38 and 39).119 The trials evaluated ALA doses ranging from 1.38 to 5.9 g/d; Jones 2014 evaluated these two doses of ALA versus placebo.180 Followup ranged from 1 to 40 months. Compliance was confirmed in four trials and was >90 percent in one (Finnegan 2003). All five trials found no significant effect of ALA supplementation on systolic BP, ranging from −7.3 to 5.2 mmHg, or on diastolic BP, ranging from −7.3 to 4.5 mmHg, or on diastolic BP, ranging from −3.9 to 1.0 mmHg, mostly with wide confidence intervals.

##### RCT Subgroup Analyses

Rodriguez-Leyva 2013 also found no differences in effect on systolic or diastolic BP in a subpopulation with systolic hypertension (>140 mmHg) compared with the study population as a whole.167

#### Marine Oil, Comparison of Different Doses

Four trials directly compared different doses of EPA+DHA, three in healthy populations,75, 136, 190 one in an at risk population (Tables 38 and 39).169 All found no differences in effects on systolic or diastolic BP between higher and lower EPA+DHA doses (1.7 vs. 0.8 g/d; 1.8 vs. 0.9 or 0.45 g/d; 3.4 vs. 1.7 g/d).

#### ALA, Comparison of Different Doses

One trial directly compared different doses of ALA (1.38 and 5.9 g/d) in an at risk population (Tables 38 and 39).180 No differences in effects on systolic or diastolic BP were found, with wide confidence intervals, between higher and lower ALA doses (5.9 vs. 1.4 g/d).

#### Marine Oils, Comparison of Different Specific n-3 FA

Grimsgaard 1998 directly compared EPA 3.8 g/d and DHA 3.6 g/d ethyl ester supplementation, finding no differences in effect at 2 months (Tables 38 and 39).61 Tatsuno 2013 compared two doses of EPA+DHA (3.4 and 1.7 g/d) and EPA 1.8 g/d (all ethyl esters); they did not report full data but stated there were no “clinically relevant changes” at 1 year.169

#### Marine Oil Versus ALA

Finnegan 2003 compared two doses of EPA+DHA (1.7 and 0.8 g/d) and ALA 4.5 g/d in a healthy population.75 (The study also tested ALA 9 g/d but that dose was excluded here because it did not meet eligibility criteria.) The comparisons between either dose of EPA+DHA and ALA found no differences in effect on systolic or diastolic BP at 4 months (Tables 38 and 39). Kromhout 2010 also compared EPA+DHA 0.4 g/d to ALA 2 g/d in a population with CVD. Neither systolic nor diastolic BP were significantly different between study arms.

#### SDA Versus Placebo

Pieters 2015 compared 1.2 g/d SDA to placebo in 32 patients at risk for CVD. At 1.5 month followup, no significant differences in change in systolic or diastolic BP were found.188

#### SDA Versus Marine Oil

Kuhnt 2014 compared 2.0 g/d SDA and 1.9 g/d EPA+DHA+DPA in 59 healthy people (broken into cohorts based on body mass index and age). At 2 month followup, no significant differences in change in systolic or diastolic BP were found.178

### Observational Studies

One study (Guangzhou) evaluated the associations between erythrocyte FA and change in systolic and diastolic BP in healthy men and women (age of 40 to 75) after about 3 years (Appendix F, Blood pressure section; Figure 35, Figure 36). Statistically significant decreases in systolic BP were found in those who took higher doses of EPA erythrocyte (Figure 35, plot #168), DHA erythrocyte (Figure 35, plot #166) and DPA erythrocyte (Figure 35, plot #167). Nonsignificant changes in systolic BP were found in those who took higher levels of ALA erythrocyte (Figure 35, plot #165). Statistically significant decreases in diastolic BP were found in those who took higher doses of EPA erythrocyte (Figure 36, plot #172), DHA erythrocyte (Figure 36, plot #170) and DPA erythrocyte (Figure 36, plot #171). Higher doses of ALA erythrocyte (Figure 36, plot #169) were not associated with a decrease in diastolic BP.

Figure 35 n-3 FA associations with systolic blood pressure: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. P values are the study-reported P value for the trend across quantiles. Where 95% confidence intervals (vertical lines) are missing, these were not reported in the studies. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, FA = fatty acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure presents individual plots from one study of omega-3 fatty acid biomarkers with change in systolic blood pressure from longitudinal observational studies. The measure of omega-3 fatty acids include ALA erythrocyte percent fatty acid, DHA erythrocyte percent fatty acid, DPA erythrocyte percent fatty acid, and EPA erythrocyte percent fatty acid. The plots replicate results reported in Appendix F.

Figure 36 n-3 FA associations with diastolic blood pressure: Observational studies

Study (or cohort) level associations between n-3 FA exposure and hazard ratio (HR) for the outcome. P values are the study-reported P value for the trend across quantiles. Where 95% confidence intervals (vertical lines) are missing, these were not reported in the studies. The 95% confidence intervals were truncated when <0.25 and >2.

White triangles = healthy adults

Abbreviations: ALA = alphalinolenic acid, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, FA = fatty acid, HR = hazard ratio, n-3 FA = omega-3 fatty acids.

This figure presents individual plots from one study of omega-3 fatty acid biomarkers with change in diastolic blood pressure from longitudinal observational studies. The measure of omega-3 fatty acids include ALA erythrocyte percent fatty acid, DHA erythrocyte percent fatty acid, DPA erythrocyte percent fatty acid, and EPA erythrocyte percent fatty acid. The plots replicate results reported in Appendix F.

## Mean Arterial Pressure

### Randomized Controlled Trials

Four RCTs reported on mean arterial pressure (MAP), all of which evaluated only marine oils (Table 40).61, 123, 136, 147 One of the trials reported MAP among its primary outcomes (Carter 2012).147

Table 40 Mean arterial pressure: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int N | Int Baseline, mg/dL | Ctrl N | Ctrl Baseline, mg/dL | Net Chg, mg/dL | Reported P value
Marine oil vs Placebo
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | Placebo | 0 | 2 mo | nd | 75 | 92.9 | 77 | 91.8 | −0.4 (−1.9, 1.1) | nd
| | DHA | 3.6 g/d (Ethyl ester) | Placebo | 0 | 2 mo | nd | 72 | 90.6 | 77 | 91.8 | 0.4 (−1.3, 2.1) | nd
Carter 2012 22707560 U.S. | Healthy (normotensive) | EPA+DHA | 1.6 EPA g/d + 1.1 DHA g/d (suppl=marine oil) | Placebo | 0 | 2 mo | Pill diary | 19 | 80 | 19 | 79 | −1 (−3.8, 1.8) | nd
| Healthy (prehypertensive) | EPA+DHA | 1.6 EPA g/d + 1.1 DHA g/d (suppl=marine oil) | Placebo | 0 | 2 mo | Pill diary | 15 | 88 | 14 | 92 | 1 (−3.8, 5.8) | nd
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 91 | 71 | 93 | 2 (−1.4, 5.4) | nd
| | EPA+DHA | 0.9 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 79 | 94 | 71 | 93 | 1 (−2.4, 4.4) | nd
| | EPA+DHA | 0.45 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 93 | 71 | 93 | −1 (−4.5, 2.5) | nd
Galan 2010 21115589 France | CVD | EPA+DHA (+/− B vitamin) | 0.6 g/d (suppl=marine oil) [E:D 2:1] | Placebo (+/− B vitamin | 0 | 4.7 y | Self-Report | 1253 | nd | 1248 | nd | 0.007(nd) | NS
Marine oil vs Marine oil (doses)
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d( suppl=marine oil) | EPA+DHA | 0.9 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 91 | 79 | 94 | 1 (−2.2, 4.2) | nd
| | EPA+DHA | 1.8 g/d (marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 91 | 80 | 93 | 3 (−0.4, 6.4) | nd
| | EPA+DHA | 0.9 g/d (marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 79 | 94 | 80 | 93 | 1.0 (−2.7, 4.7) | nd
EPA vs DHA
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | DHA | 3.6 g/d (Ethyl ester) | 2 mo | nd | 75 | 92.9 | 72 | 90.6 | −0.8 (−2.5, 0.9) | nd

Abbreviations: Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, ND = no data, NS = not significant, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### Marine Oil Versus Placebo

##### Healthy Population

Three trials evaluated healthy populations, including the previously described trial that compared EPA 3.8 g/d and DHA 3.6 g/d ethyl esters to placebo,61 the trial of 2.7 g/d EPA+DHA in two healthy subgroups (with normotension or prehypertension),147 and the comparison of 1.8 g/d, 0.9 g/d, and 0.45 g/d versus placebo.136 Followup was either 2 months or 1 year. Baseline MAP ranged from 79 to 92 mmHg. All trials found no significant effect on MAP, with estimates of net change ranging from −1 to 2 mmHg.

##### CVD Population

One trial of 0.6 g/d EPA+DHA versus placebo (with or without B vitamin) was conducted in 2501 people with a history of CVD.123 At 4.7 years, there was no difference in MAP between the two groups.

##### RCT Subgroup Analyses

Carter 2012 found no differences in effect between two subpopulations of those with prehypertension or normal BP.147

#### Marine Oil, Comparison of Different Doses

One trial directly compared different doses of EPA+DHA in healthy populations.136 Sanders 2011 found no differences in effects on MAP between higher and lower EPA+DHA doses (1.8, 0.9 or 0.45 g/d).

#### Marine Oils, Comparison of Different Specific n-3 FA

Grimsgaard 1998 directly compared EPA 3.8 g/d and DHA 3.6 g/d ethyl ester supplementation, finding no differences in effect at 2 months.61

### Observational Studies

Observational studies did not evaluate MAP.

## Low Density Lipoprotein Cholesterol

### Randomized Controlled Trials

Forty-five RCTs provided data on effect of n-3 FA on LDL-c (Table 41).46, 51, 53, 56, 58, 61, 62, 70, 75, 76, 80, 85, 90, 94, 96, 97, 99, 103, 105, 107, 116, 119–121, 128, 136, 146, 151, 152, 156, 160, 161, 166, 167, 169, 173, 174, 177, 178, 180, 184, 187–189, 194 Only six of the trials reported LDL-c among their primary outcomes (Caslake 2008, Damsgaard 2008, Lungershausen 1994, Olano-Martin 2010, Rasmussen 2006, Sirtori 1997).53, 58, 85, 94, 97, 107

Table 41 Low density lipoprotein cholesterol: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int N | Int Baseline, mg/dL | Ctrl N | Ctrl Baseline, mg/dL | Net Chg, mg/dL (95% CI) | Reported P value
Total n-3 FA vs Placebo
Jones 2014 24829493 Canada | At risk | ALA + EPA+DHA | ALA: 1.2 g/d, EPA: 0.1 g/d, DHA: 3.5 g/d, DPA: 1.4 g/d (canola+DHA) | Placebo | 0 | 4 wk | Assessed by coordinators | 130 | 129.3 | 130 | 129.3 | 11.3 (1.7, 20.8) | <0.05
Kromhout 2010 20929341 Netherlands | CVD | ALA + EPA+DHA | 0.4 g/d EPA+DHA; 2 g/d ALA (Marine oil, plant oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1212 | 98 | 1236 | 100 | 0.8 (−2.4, 4.0) | NS
Marine oil vs Placebo
Ras 2014 25122648 Scandinavia | Healthy | EPA+DHA±DPA | 0.9 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 64 | 153.7 | 64 | 145.6 | −1.9 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.3 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 62 | 151.7 | 64 | 145.6 | −1.5 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 62 | 145.6 | 64 | 145.6 | −3.1 (nd) | nd
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | Placebo | 0 | 2 mo | pill count | 75 | 156.8 | 77 | 156.0 | −5.4 (−11.3, 0.5) | nd
| | DHA | 3.6 g/d (Ethyl ester) | Placebo | 0 | 2 mo | pill count | 72 | 156.8 | 77 | 156.0 | 0.4 (−5.4, 6.2) | nd
Olano-Martin 2010 19748619 UK | Healthy | EPA | 3.3 g/d (Marine oil) | Placebo | 0 | 1 mo | nd | 38 | 136.3 | 38 | 136.7 | 3.1 (−12, 18.2) | NS
| | DHA | 3.7 g/d (Marine oil) | Placebo | 0 | 1 mo | nd | 38 | 139.4 | 38 | 136.7 | 6.2 (−5.1, 17.5) | NS
Harrison 2004 15853118 Scotland, UK | At risk | DHA+/− soy protein | Placebo+/− soy protein | Placebo+/− soy protein | 0 | 1.25 mo | Food diary (biomarker confirmation) | 101 | 218.1 | 112 | 191.1 | −27.4 (−63.8, 8.9)
Carrepeiro 2011 21561620 Brazil | Healthy | EPA+DHA + Statin | 2.4 g/d (Marine oil) | Placebo + Statin | 0 | 6 mo | nd | 20 | 133.4 | 20 | 116.9 | −1.5 (−3.5, 0.4) | 0.128
| | EPA+DHA | 2.4 g/d (Marine oil) | Placebo | 0 | 6 mo | nd | 23 | 136 | 23 | 144.5 | −0.8 (−2.8, 1.2) | 0.431
Caslake 2008 18779276 UK | Healthy | EPA+DHA | 1.8 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 312 | 148.5 | 312 | 147.2 | 2.7 (−3.0, 8.4) | <0.017
| | EPA+DHA | 0.7 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 312 | 148.5 | 312 | 147.2 | 2.7 (−2.6, 8.1) | <0.017
Damsgaard 2008 18492834 Scandinavia | Healthy | EPA+DHA + high LA | 3.1 g/d (Marine oil) [E:D 1.64] | Placebo + high LA | 0 | 2 mo | nd | 17 | 99.6 | 16 | 90 | 3.5 (−9, 15.9)
| | EPA+DHA + low LA | 3.1 g/d (Marine oil) [E:D 1.64] | Placebo + low LA | 0 | 2 mo | nd | 14 | 102.1 | 17 | 104.6 | 5.4 (−15.1, 25.9)
Finnegan 2003 12663273 UK | | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | Placebo | 0 | 6 mo | Pill count | 31 | 132.05 | 30 | 140.15 | 11.7 (−3.2, 26.7) | nd
| Healthy | EPA+DHA | 0.8 g/d (marine oil margarine) | Placebo | 0 | 6 mo | Pill count | 30 | 131.66 | 30 | 140.15 | −2.3 (−11.0, 6.4) | nd
Grieger 2014 24454276 Australia | Healthy | EPA+DHA | 0.8 g/d (fish diet) | Placebo | EPA: 0.017 g/d, DHA: 0.004 g/d (red meat diet) | 8 wk | Weighed food records | 43 | 123.55 | 37 | 127.41 | 11.6 (0.9, 22.3) | nd
Rasmussen 2006 16469978 Scandinavia, Australia | Healthy | EPA+DHA (MUFA diet) | EPA 3.6 g/d, 2.4 g/d DHA (Marine oil) | Placebo (MUFA diet) | 0 | 3 mo | Dietary records (biomarker confirmation) | 39 | 141 | 40 | 141 | 5% (nd) | nd
| Healthy | EPA+DHA (SFA diet) | EPA 3.6 g/d, 2.4 g/d DHA (Marine oil) | Placebo (SFA diet) | 0 | 3 mo | | 41 | 141 | 42 | 141 | 7.1% (nd) | nd
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 123.6 | 71 | 127.4 | 3.9 (−5.6, 13.6) | nd
| | EPA+DHA | 0.9 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 81 | 123.6 | 71 | 127.4 | 0 (−10.2, 10.2) | nd
| | EPA+DHA | 0.45 g/d ( suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 123.6 | 71 | 127.4 | 7.7 (−2.5, 17.9) | nd
Shaikh 2014 25185754 U.S. | Healthy | EPA+DHA | 3.6 g/d [E:D 6:1] | Placebo | 0 | 2 mo | Pill count | 36 | 115.4 | 32 | 103.1 | 12.7 (−3.3, 28.8) | 0.12
Tardivo 2015 25394692 Brazil | Healthy | EPA+DHA | 0.9 g/d [E:D 3:2] | Placebo | 0 | 6 mo | Pill count | 44 | 134.8 | 43 | 134.3 | −5.7 (−20.7, 9.3) | nd
Vazquez 2014 24462043 Spain | Healthy | EPA+DHA | 0.64 g/d [E:D 1:3] | Placebo | 0 | 2 mo | Assessed by trained dieticians at each visit | 273 | 119.8 | 273 | 119.8 | −3.01 (−7.2, 1.1) | 0.046
Bosch 2012 22686415 Canada | At risk | EPA+DHA | EPA: 0.465 g/d, DHA: 0.375 g/d (Marine oil) [E:D 1.24] | Placebo | 0 | 6 y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 6281 | 112 | 6255 | 112 | 0.6 (−1.6, 2.8) | 0.44
Ballantyne 2012 22819432 U.S. | At risk | EPA+DHA | 4 g/d (marine oil) | Placebo | 0 | 3 mo | nd | 225 | 82 | 226 | 84 | −6.3 (−11.6, −1.0) | 0.007
| | EPA+DHA | 2 g/d (marine oil) | Placebo | 0 | 3 mo | nd | 233 | 82 | 226 | 84 | −3.8 (−9, 1.4) | 0.09
Derosa 2009 19397392 Italy | At risk | EPA+DHA | EPA: 0.9 g/d, DHA: 1.5 g/d (marine oil) | Placebo | 0 | 6 mo | Pill count | 168 | 148.5 | 165 | 149.9 | 0.7 (−0.8, 2.2) | nd
Ebrahimi 2009 19593941 Iran | At risk | EPA+DHA | EPA: 0.18, DHA: 0.12 (marine oil) | Placebo | 0 | 6 mo | nd | 47 | 145.6 | 42 | 143.2 | 5.4 (−7.2, 18.0) | nd
Holman 2009 19002433 UK | At risk | EPA+DHA | 2 g/d | Placebo | 0 | 4 mo | Pill count | 371 | 123.6 | 361 | 121.6 | −1.2 (−11.1, 8.8) | 0.82
Jones 2014 24829493 Canada | At risk | EPA+DHA (+ALA) | EPA: 0.1 g/d, DHA: 3.5 g/d, DPA: 1.4 g/d (canola+DHA) | (ALA) | 0 | 4 wk | Assessed by coordinators | 130 | 129.3 | 130 | 129.3 | 6.9 (−2.7, 16.5) | <0.05
Kastelein 2014 24528690 Europe | At risk | EPA+DHA | EPA: 2.20 g/d, DHA: 0.80 g/d | Placebo | 0 | 12 wk | Pill count | 99 | 90.3 | 98 | 78.2 | 15.2 (7.1, 23.2) | <0.001
| | EPA+DHA | EPA: 1.65 g/d, DHA: 0.60 g/d | Placebo | 0 | 12 wk | Pill count | 97 | 81.0 | 98 | 78.2 | 9.2 (1.9, 16.6) | NS
| | EPA+DHA | EPA: 1.10 g/d, DHA: 0.40 g/d | Placebo | 0 | 12 wk | Pill count | 99 | 77.3 | 98 | 78.2 | 12.5 (5.2, 19.8) | <0.01
Liu 2003 Sweden | At risk | EPA+DHA | EPA: 1.7 g/d, DHA: 1.1 g/d | Placebo | 0 | 12 wk | Pill count | 29 | 180.31 | 22 | 173.75 | 5.4 (−13.3, 24.1) | NS
| | EPA+DHA + simvastatin | EPA: 1.7 g/d, DHA: 1.1 g/d | Placebo + simvastatin | 0 | 12 wk | Pill count | 19 | 173.36 | 18 | 172.20 | 5.0 (−17, 27.1) | NS
Lungershausen 1994 7852747 Australia | At risk | EPA+DHA | EPA: 1.9 g/d, DHA: 1.5 g/d (marine oil) | Placebo | 0 | 6 wk | Pill count | 42 | 155.98 | 42 | 155.98 | 6.6 (−7.4, 20.6) | 0.359
Maki 2010 20451686 U.S. | At risk | EPA+DHA (+simvastatin) | EPA: 1.86 g/d, DHA: 1.5 g/d | Placebo (+simvastatin) | 0 | 8 wk | Pill count | 122 | 89.2 | 132 | 92.3 | 3.4 (−2.1, 8.9) | 0.052
Maki 2013 23998969 U.S. | At risk | EPA+DHA | 4 g/d total oil (free FA oil) [nd] | Placebo | 0 | 1.5 mo | Biomarker confirmation | 207 | 93.6 | 211 | 91.7 | −0.5 (−4.1, 3.1) | NS
| | EPA+DHA | 2 g/d total oil (free FA oil) [nd] | Placebo | 0 | 1.5 mo | Biomarker confirmation | 209 | 92.3 | 211 | 91.7 | 3.2 (−0.4, 6.8) | <0.05
Oh, 2014, 25147070 Korea | At risk | EPA+DHA | 4 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 44 | 110 | 42 | 111 | 1.0 (−13.2, 15.2)
| | EPA+DHA | 2 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 43 | 109 | 42 | 111 | 6.0 (8.1, 20.1)
| | EPA+DHA | 1 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 44 | 109 | 42 | 111 | 3.0 (11.1, 17.1)
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | 0.85 g/d (Marine oil) | Placebo | 0 | 5 y | Self-reported | 6239 | 131.8 | 6266 | 132.5 | −0.4 (−1.8, 1.1) | 0.63
Shaikh 2014 25185754 U.S. | At risk | EPA+DHA | 3.6 g/d [E:D 6:1] | Placebo | 0 | 2 mo | Pill count | 20 | 115.4 | 22 | 101.93 | 13.9 (−2.2, 30.0) | 0.12
Shidfar 2003 12847992 Iran | At risk | EPA+DHA | EPA 0.5 g/d, DHA 0.31 g/d (suppl) [E:D 1.6] | Placebo | 0 | 2.5 mo | nd | 16 | 159.6 | 19 | 167.4 | −4.2 (−34.9, 26.5)
| | EPA+DHA +vitamin C | EPA 0.5 g/d, DHA 0.31 g/d (suppl) [E:D 1.6] | Placebo + vitamin C | 0 | 2.5 mo | nd | 16 | 150.8 | 17 | 160.6 | 10.3 (−18.8, 39.4)
Sirtori 1997 9174486 Italy | At risk | EPA+DHA | 2.57 g/d (Marine oil) [E:D 1.45] | Placebo | 0 | 6 mo | nd | 470 | 135.1 | 465 | 135.1 | 6.6 (6.3, 6.8)
Tierney 2011 20938439 Europe | At risk | EPA+DHA | EPA 0.26 g/d, DHA 0.19 g/d (suppl) [E:D 1.5] | Placebo | 0 | 3 mo | Pill count and plasma FA | 100 | 127.80 | 106 | 122.39 | −5.41 (−17.73, 6.91) | nd
Vecka 2012 23183517 Czech | At risk | EPA+DHA | 2.58 g/d (Marine oil) [E:D 2.74] | Placebo | 0 | 1.5 mo | nd | 60 | nd | 60 | nd | 10.4 (9.8, 11.1) [difference of final values] | <0.01
Yokoyama 2007 17398308 Japan | At risk (no previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 8841 | 181.5 | 8862 | 181.5 | 0 (−0.9, 0.9) | 0.493
Eritsland 1996 8540453 Norway | CVD | EPA+DHA | 3.4 g/d (Marine Oil) | Placebo | 0 | 9 mo | nd | 260 | 180 | 251 | 181 | 3.8 (−3.4, 11.4) | nd
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1192 | 102 | 1236 | 100 | −0.8 (−4.0, 2.4) | NS
| | EPA+DHA (+ALA) | 0.4 g/d (Marine oil) [E:D 3:2] | (ALA) | 0 | | | 1212 | 98 | 1197 | 99 | 0.4 (−2.8, 3.6) | nd
Marchioli 2002 11997274 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Marine Oil) | Placebo | 0 | 42 mo | Measured at followup times | 5666 | 136 | 5668 | 137 | 2 (nd) | nd
Rauch 2010 21060071 Germany | CVD | EPA+DHA | 1 g/d (Marine oil) [E:D ratio 0.460:0.380] | Placebo | 0 | 1 y | Pill count | 1925 | Not reported | 1893 | Not reported | 0 (nd) | ‘Did not differ significantly between the study groups’
Sacks 1995 7759696 U.S. | CVD | EPA+DHA | EPA: 2.88 g/d DHA: 3.12 g/d (Marine oil) | Placebo | 0 | 2.4 y | Pill count (80% n3, 90% placebo) | 31 | 122 | 28 | 117 | 5.0 (−9.1, 19.1) | Nd
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | EPA: 0.386–0.401 g/d DHA: 0.464–0.481 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 | 3.9 y | Measured at clinical exams, patient was compliant if drug administered for 80% of days. Both groups had ~30% compliance | 3494 | nd | 3481 | nd | “no differences” | Nd
Von Schacky 1999 10189324 Canada | CVD | EPA+DHA | 3.3 g/d | Placebo | 0 | 12 mo | Pill count | 112 | 158.3 | 111 | 154.4 | 5.8 (−5.7, 17.2) | NS
Yokoyama 2007 17398308 Japan | CVD | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 485 | 179.5 | 457 | 179.5 | 0.7 (−2.5, 4.1) | 0.602
Marine oil vs Marine oil (doses)
Ras 2014 25122648 Scandinavia | Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | EPA+DHA±DPA | 0.9 g/d EPA+DHA | 1 mo | nd | 62 | 145.6 | 64 | 153.7 | −1.2 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | EPA+DHA±DPA | 1.3 g/d EPA+DHA | 1 mo | nd | 62 | 145.6 | 62 | 151.7 | −1.5 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.3 g/d EPA+DHA | EPA+DHA±DPA | 0.9 g/d EPA+DHA | 1 mo | nd | 62 | 151.7 | 62 | 153.7 | 0.39 (nd) | nd
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | EPA+DHA | 0.8 g/d (marine oil margarine) | 6 mo | Pill count | 31 | 132.05 | 30 | 131.66 | 14.0 (0.4, 27.7) | nd
Caslake 2008 18779276 UK | Healthy | EPA+DHA | 1.8 g/d (Marine oil) | EPA+DHA | 0.7 g/d (Marine oil) | 2 mo | Pill count | 312 | 148.5 | 312 | 148.5 | 0 (−6.3, 6.3) | NS
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (Marine oil) | EPA+DHA | 0.9 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 123.6 | 81 | 123.6 | 3.9 (−6.4, 14.1) | nd
| | EPA+DHA | 1.8 g/d (Marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 123.6 | 80 | 123.6 | −11.6 (−22.5, −0.66) −3.9 (−13.5, 5.8) | nd
| | EPA+DHA | 0.9 g/d (Marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 81 | 123.6 | 80 | 123.6 | −7.7 (−18.6, 3.2) | nd
Ballantyne 2012 22819432 U.S. | At risk | EPA+DHA | 4 g/d (marine oil) | EPA+DHA | 2 g/d (Marine oil) | 3 mo | nd | 225 | 82 | 233 | 82 | −4
Kastelein 2014 24528690 Europe | At risk | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | 3 mo | Pill count | 99 | 90.3 | 97 | 81.0 | 5.9 (−2.6, 14.5) | nd
| | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | 3 mo | Pill count | 99 | 90.3 | 99 | 77.3 | 2.7 (−5.9, 11.2) | nd
| | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | 3 mo | Pill count | 97 | 81.0 | 99 | 77.3 | −3.3 (−11.1, 4.6) | nd
Oh, 2014, 25147070 Korea | At risk | EPA+DHA | 4 g/d (Marine oil) | EPA+DHA | 2 g/d (Marine oil) | 2 mo | Pill count | 44 | 110 | 43 | 109 | −5 (18.7, 8.8)
| | EPA+DHA | 4 g/d (Marine oil) | EPA+DHA | 1 g/d (Marine oil) | 2 mo | Pill count | 44 | 110 | 44 | 109 | 1 (−13.1, 15.1)
| | EPA+DHA | 2 g/d (Marine oil) | EPA+DHA | 1 g/d (Marine oil) | 2 mo | Pill count | 43 | 109 | 44 | 109 | 6 (−8.1, 20.1)
Tatsuno 2013 23725919 Japan | At Risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 12 wk | Pill count | 210 | 125.7 | 206 | 127.4 | 1.3 (−4.4, 7.0) | nd
| | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 1 y | nd | 170 | nd | 165 | nd | 2.8% (−1.3, 6.9)
Maki 2013 23998969 U.S. | At risk | EPA+DHA | 4 g/d total oil (free FA oil) [nd] | EPA+DHA | 2 g/d total oil (free FA oil) [nd] | 1.5 mo | Biomarker confirmation | 207 | 93.6 | 209 | 92.3 | −3.7 (−7.3, −0.1)
Marine oil vs Marine oil (miscellaneous)
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | DHA | 3.6 g/d (Ethyl ester) | 2 mo | pill count | 72 | 156.8 | 77 | 156.8 | −5.8 (−11.7, 0.1) | nd
Olano-Martin 2010 19748619 UK | Healthy | EPA | 3.3 g/d (Marine oil) | DHA | 3.7 g/d (Marine oil) | 1 mo | nd | 38 | 136.3 | 38 | 139.4 | 3.1 (−12.5, 18.7)
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA | 1.68 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | 3.8% (−0.1, 7.9) | nd
| | EPA+DHA | 1.8 g/d (Ethyl esters) E:D 1.24 | EPA | 1.68 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | 1.1% (−2.6, 4.7) | nd
ALA vs Placebo
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | ALA | 4.5 g/d (ALA margarine) | 6 mo | Pill count | 31 | 132.05 | 30 | 137.07 | 14.5 (0.4, 28.6) | NS
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 0.8 g/d (marine oil margarine) | ALA | 4.5 g/d (rapeseed oil margarine) | 6 mo | Pill count | 30 | 131.66 | 30 | 137.07 | 0.4 (−10.8, 11.6) | NS
Baxheinrich 2012 22894911 Germany | At risk | ALA | 3.46 g/d (plant oil) | Placebo | ALA: 0.78 g/d | 6 mo | Dietary records | 40 | 132.05 | 41 | 134.75 | 1.9 (−12.0, 15.8) | 0.181
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | Placebo | 0.2 g/d (CornSaff) | 4 wk | Assessed by coordinators | 130 | 129.3 | 130 | 129.3 | 5.7 (−3.9, 15.3) | NS
| | ALA | 1.4 g/d (canolaOleic) | Placebo | 0.2 g/d (CornSaff) | 4 wk | Assessed by coordinators | 130 | 129.3 | 130 | 129.3 | 4.4 (−5.4, 14.2) | NS
Rodriguez-Leyva 2013 24126178 Canada | At risk | ALA | 5.9 g/d (flaxseed) | Placebo | 0 | 1 y | Plasma ALA and enterolignan levels | 43 | 96.5 | 41 | 100.4 | 0 (−16.6, 16.6) | 0.19
Kromhout 2010 20929341 Netherlands | CVD | ALA | 2 g/d (plant oil) | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1197 | 99 | 1236 | 100 | 0.4 (−2.8, 3.6) | NS
| | ALA (+EPA+DHA) | 2 g/d (plant oil) | (EPA+DHA) | 0 | | | 1212 | 98 | 1192 | 102 | 1.5 (−1.7, 4.8) | nd
EPA+DHA vs ALA
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 0.8 g/d (marine oil margarine) | ALA | 4.5 g/d (rapeseed oil margarine) | 6 mo | Pill count | 30 | 131.66 | 30 | 137.07 | 14.5 (0.4, 28.6) | NS
| | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | ALA | 4.5 g/d (ALA margarine) | 6 mo | Pill count | 31 | 132.05 | 30 | 137.07 | 0.4 (−10.8, 11.6) | NS
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | ALA | 2 g/d (plant oil) | 40 mo | Audit of unused margarine tubs returned | 1192 | 102 | 1197 | 99 | −1.2 (−4.4, 2.1) | nd
ALA vs ALA (doses)
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | ALA | 1.4 g/d (canolaOleic) | 4 wk | Assessed by coordinators | 130 | 129.34 | 130 | 129.34 | 1.3 (−8.3, 11) | .
SDA vs Placebo
Pieters 2015 25226826 Netherlands | At risk | SDA | 1.2 g/d (suppl) | Placebo | 0 | 1.5 mo | nd | 32 | 141.31 | 32 | 143.47 | −1.55 (−6.20, 3.10) | 0.46
SDA vs Marine oil
Kuhnt 2014 24553695 Germany | Healthy | SDA | 2.0 g/d (suppl) | EPA+DHA+DPA | 1.9 g/d (suppl: marine oil) | 2 mo | nd | 20 | 98.07 | 10 | 96.29 | −3.87 (−14.74, 22.48)
Kuhnt 2014 24553695 Germany | Healthy | SDA | 2.0 g/d (suppl) | EPA+DHA+DPA | 1.9 g/d (suppl: marine oil) | 2 mo | nd | 20 | 136.68 | 9 | 118.92 | −10.44 (−13.29, 34.17)

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FA = fatty acid(s), FFQ = food frequency questionnaire, Int = intervention, MUFA = monounsaturated fatty acid, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, PMID = PubMed Identification number, RCT = randomized controlled trial, SDA = stearidonic acid, SFA = saturated fatty acids.

#### Total n-3 FA Versus Placebo

Two trials compared total n-3 FA (ALA+EPA+DHA) versus placebo, following 2708 patients for 1 and 40 months; one in people at increased risk for CVD,180 one in people with CVD.119 Baseline LDL-c measurements were 100 and 129 mg/dL. Compliance was measured in all studies, but not reported. One trial in an at risk population found a statistically significant increase in LDL-c with combined ALA 1.2 g/d (canola oil) and EPA+DHA+DPA (11.3 mg/dL; 95% CI 1.7 to 20.8).180. The trial in a CVD population found no significant effect on LDL-c with ALA 2 g/d and EPA+DHA 0.4 g/d.119

#### Marine Oil Versus Placebo

Thirty-nine trials evaluated the effect of marine oils versus placebo on LDL-c.46, 51, 53, 56, 58, 61, 62, 70, 75, 76, 80, 85, 90, 94, 96, 97, 99, 103, 105, 107, 116, 119–121, 128, 136, 146, 151, 156, 160, 166, 173, 174, 177, 180, 184, 187, 189, 194 Doses of EPA+DHA±DPA ranged from 0.3 to 6 g/d (median 2.4 g/d) and followup time ranged from 1 month to 6 years (median 3 months). Across populations, the meta-analyzed summary net difference in LDL-c with EPA+DHA versus placebo (or equivalent) was a statistically significant 1.98 mg/dL (95% CI 0.38 to 3.58) (Figure 37).

Figure 37 Low density lipoprotein cholesterol: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, LDL = low density lipoprotein, n-3 FA = omega-3 fatty acids, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure presents meta-analysis results for low density lipoprotein cholesterol in randomized controls that looked at comparisons between marine oil omega-3 fatty acid intake versus a placebo. The meta-analysis was divided into healthy (seventeen cohorts), at risk (23 cohorts) and cardiovascular disease (two cohorts) populations. Subgroup meta-analysis of the healthy, at risk and cardiovascular disease populations yielded nonsignificant summaries of 2.70 (−0.64, 6.03), 2.34 (−0.82, 5.49) and 1.92 (−1.05, 4.89), respectively. However, the overall summary 1.98 (0.38, 3.58) was significant. Net differences across studies were mostly homogeneous.

##### Healthy Population

Sixteen of the trials of marine oils versus placebo were conducted in healthy populations, comprising data from 3,749 individuals with mean baseline LDL-c ranging from 100 to 218 and followup duration from 1 to 12 months.61, 75, 80, 85, 94, 97, 103, 107, 128, 136, 146, 173, 174, 187, 189 Two studies compared both purified EPA (3.3 and 3.8 g/d) and DHA (3.6 and 3.7 g/d) ethyl esters, separately, to placebo;61, 107 all other evaluated supplements with both EPA+DHA, with doses ranging from 0.45 to 6 g/d. Compliance was verified with pill counts, dietary records, or biomarker confirmation in six of the studies. All but one RCT found no significant effect of EPA+DHA on LDL-c; net LDL-c varied between −5.4 and 12.7 mg/dL. The pooled effect size was a nonsignificant 2.70 mg/dL (95% CI −0.64 to 6.03).

##### At-Risk-for-CVD Population

Twenty of the trials were conducted in populations at increased risk of CVD, comprising data from 48,762 individuals with mean baseline LDL-c ranging from 78.2 to 191.1 and followup duration from 1 month to 6 years.46, 53, 58, 76, 80, 90, 99, 103, 105, 116, 120, 146, 156, 160, 166, 177, 180, 187, 194, 195 One study compared purified DHA (2 g/d) to placebo;80 all other evaluated supplements with both EPA+DHA, with doses ranging from 0.3 to 6 g/d. Compliance was verified with pill counts, dietary records, self-report or biomarker confirmation in 11 of the studies. All but two RCTs found no significant effect of EPA+DHA on LDL-c; net change LDL-c varied between −27.4 and 10.4 mg/dL. The pooled effect size was a nonsignificant 2.34 mg/dL (95% CI −0.82 to 5.49).

##### CVD Population

Eight of the trials were conducted in people with CVD, comprising data from 28,699 individuals with mean baseline LDL-c ranging from 99 to 181 mg/dL and followup duration from 9 months to 4.6 years.51, 56, 62, 70, 90, 96, 119, 121 Compliance was verified in four of the studies, by pill count or equivalent. All trials found no significant effect on LDL-c; net change LDL-c varied from −0.8 to 5.8 mg/dL. The pooled effect size was a nonsignificant 1.92 mg/dL (95% CI −1.05 to 4.89).

##### RCT Subgroup Analyses

Eight of the trials compared effects of marine oils in different subgroups of participants; five reported statin vs no statin,46, 99, 119, 128, 156 one with or without vitamin C,76 one men vs women,97 one older vs younger age,97 and one saturated FA diet vs monosaturated FA diet.85 All found (or reported) no significant interactions (differences in effect) by subgroup or cointervention.

By meta-regression, across studies there were no significant differences in effect (interactions) by LDL-c baseline (P=0.93), n-3 FA dose (P=0.93), followup duration (P=0.29), or population (at risk P=0.51; CVD P=0.98).

#### Marine Oil, Comparison of Different Doses

Ten RCTs directly compared different doses of marine oils (EPA+DHA),75, 97, 136, 151, 161, 166, 169, 177, 184, 194, 195 between 0.9 and 4 g/d. All comparisons were nonsignificant for effect on LDL-c, with estimates of differences ranging from −11.6 mg/dL (95% CI −22.5 to −0.66; 1.8 vs. 0.45 g/d) to 14 mg/dL (95% CI 0.4 to 27.7; 1.7 vs. 0.8 g/d).

#### ALA Versus Placebo

Five trials compared ALA to placebo (or equivalent) in a healthy population,75 at-risk populations,152, 167, 180 and a population with CVD.119 In total, there were 5,452 participants followed for 1 to 40 months, with ALA doses of 0.4 to 5.9 g/d. None of the trials found a significant effect of ALA on LDL-c, with net changes ranging from −1.2 to 14.5 mg/dL, mostly with wide confidence intervals.

#### ALA, Comparison of Different Doses

One trial compared ALA 5.9 and 1.4 g/d and found no difference in effect on LDL-c with wide confidence intervals (1.3 mg/dL; 95% CI −8.3 to 11).180

#### Comparison of Different Specific n-3 FA

Two trials directly compared EPA (3.8 or 3.3 g/d) to DHA (3.6 or 3.7 g/d),61, 107 one of which evaluated EPA and DHA ethyl esters,61 the other evaluated EPA- and DHA-enriched oils.107 Both found larger, but nonsignificant, relative reductions in LDL-C with EPA than DHA (net difference −5.8 [95% CI −11.7 to 0.1]; −6.2 [95% CI −21.8 to 9.4]). One trial compared two doses of EPA+DHA (3.4 and 1.7 g/d) to EPA 1.8 g/d (all ethyl esters),169 with no significant differences between marine oil formulations. Two trials compared EPA+DHA to ALA, one comparing two doses of EPA+DHA (1.7 and 0.8 g/d) to ALA 4.5 g/d,75 one comparing 0.4 g/d EPA+DHA to 2 g/d ALA.119 All comparisons were reported as nonsignificant, but the comparison of the higher dose marine oil in Finnegan 2003 found a large relative increase in LDL-c with a significant estimated CI (14.0 mg/dL; 95% CI 0.4 to 27.7).

#### SDA Versus Placebo

Pieters 2015 compared 1.2 g/d SDA to placebo in 32 patients at risk for CVD. At 1.5 month followup, no significant differences in change in LDL-c were found.188

#### SDA Versus Marine Oil

Kuhnt 2014 compared 2.0 g/d SDA and 1.9 g/d EPA+DHA+DPA in 59 healthy people (broken into cohorts based on body mass index and age). At 2 month followup, no significant differences in change in LDL-c ratios were found.178

### Observational Studies

Observational studies did not evaluate LDL-c.

## High Density Lipoprotein Cholesterol

### Randomized Controlled Trials

Forty-six RCTs provided data on effect of n-3 FA on HDL-c (Table 42). 46, 48, 51, 53, 55, 56, 58, 61, 62, 67, 70, 75, 76, 80, 90, 94, 96, 97, 99, 103, 105, 107, 115, 116, 119, 120, 128, 136, 146, 151, 152, 156, 160, 167, 173, 174, 177–180, 184, 187–189, 194 Only four of the trials reported HDL-c among their primary outcomes (Damsgaard 2008, Harrison 2004, Lungershausen 1994, Sirtori 1997).53, 58, 80, 94

Table 42 High density lipoprotein cholesterol: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int N | Int Baseline, mg/dL | Ctrl N | Ctrl Baseline, mg/dL | Net Chg, mg/dL (95% CI) | Reported P value
Total n-3 FA vs. Placebo
Jones 2014 24829493 Canada | At risk | ALA + EPA+DHA | ALA: 1.2 g/d, EPA: 0.1 g/d, DHA: 3.5 g/d, DPA: 1.4 g/d (canola+DHA) | Placebo | 0.2 g/d (CornSaff) | 4 wk | Assessed by coordinators | 130 | 47.1 | 130 | 47.1 | 3.9 (1.5, 6.2) | <0.05
Kromhout 2010 20929341 Netherlands | CVD | ALA + EPA+DHA | 0.4 g/d EPA+DHA; 2 g/d ALA (Marine oil, plant oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1212 | 50 | 1236 | 50 | −0.4 (−1.5, 0.7) | NS
Marine oil vs Placebo
Ras 2014 25122648 Scandinavia | Healthy | EPA+DHA±DPA | 0.9 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 64 | 61.0 | 64 | 64.9 | 0.7 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.3 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 62 | 63.7 | 64 | 64.9 | 3.5 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 62 | 63.3 | 64 | 64.9 | 3.9 (nd) | nd
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | Placebo | 0 | 2 mo | pill count | 75 | 51.35 | 77 | 54.44 | 0.8 (−0.6, 2.2) | 0.4
| | DHA | 3.6 g/d (Ethyl ester) | Placebo | 0 | 2 mo | pill count | 72 | 52.51 | 77 | 54.44 | 2.7 (1.2, 4.2) | 0.0005
Olano-Martin 2010 19748619 UK | Healthy | EPA | 3.3 g/d (Marine oil) | Placebo | 0 | 1 mo | nd | 38 | 51.0 | 38 | 51.4 | −0.4 (−6.0, 5.3)
| | DHA | 3.7 g/d (Marine oil) | Placebo | 0 | 1 mo | nd | 38 | 50.6 | 38 | 51.4 | 1.2 (−2.7, 5.0)
Harrison 2004 15853118 Scotland | At risk | DHA+/− soy protein | 2 g/d (food fortification) | Placebo+/− soy protein | 0 | 1.25 mo | Food diary (biomarker confirmation) | 101 | 63.7 | 112 | 63.7 | 2.3 (−3.9, 8.5) | nd
Carrepeiro 2011 21561620 Brazil | Healthy | EPA+DHA + Statin | 2.4 g/d (Marine oil) | Placebo + Statin | 0 | 6 mo | nd | 20 | 50.1 | 20 | 50.6 | 1.9 (nd)
| | EPA+DHA | 2.4 g/d (Marine oil) | Placebo | 0 | 6 mo | nd | 23 | 52.4 | 23 | 49.6 | −1.3 (nd)
Caslake 2008 18779276 UK | Healthy | EPA+DHA | 1.8 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 312 | 65.6 | 312 | 65.6 | 2.3 (0.2, 4.5) | <0.017
| | EPA+DHA | 0.7 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 312 | 65.2 | 312 | 65.6 | 2.3 (0.2, 4.5) | <0.017
Damsgaard 2008 18492834 Scandinavia | Healthy | EPA+DHA + high LA | 3.1 g/d (Marine oil) [E:D 1.64] | Placebo + high LA | 0 | 2 mo | nd | 17 | 57.1 | 16 | 52.5 | 0.4 (−5.7, 6.4)
| | EPA+DHA + low LA | 3.1 g/d (Marine oil) [E:D 1.64] | Placebo + low LA | 0 | 2 mo | nd | 14 | 57.9 | 17 | 57.9 | 3.1 (−7.8, 14)
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | Placebo | 0 | 6 mo | Pill count | 31 | 51.74 | 30 | 52.12 | 1.4 (−2.1, 4.8) | nd
| | EPA+DHA | 0.8 g/d (marine oil margarine) | Placebo | 0 | 6 mo | Pill count | 30 | 52.90 | 30 | 52.12 | 2.8 (−0.2, 5.7) | nd
Grieger 2014 24454276 Australia | Healthy | EPA+DHA | 0.8 g/d (fish diet) | Placebo | EPA: 0.017 g/d, DHA: 0.004 g/d (red meat diet) | 8 wk | Weighed food records | 43 | 65.64 | 37 | 61.776 | 0 (−10.7, 10.7) | nd
Sacks 1994 8021472 U.S. | Healthy | EPA+DHA | 3 g/d (Marine oil) [E:D 1.44:0.96] ] | Placebo | 0 | 6 mo | Pill count | 84 | 46 | 84 | 45 | 1.8 (−1.0, 4.5) | NS
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 65.6 | 71 | 61.8 | 3.9 (−1.6, 9.3) | nd
| | EPA+DHA | 0.9 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 81 | 65.6 | 71 | 61.8 | 0 (−5.5, 5.5) | nd
| | EPA+DHA | 0.45 g/d ( suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 61.8 | 71 | 61.8 | 3.9 (−1.6, 9.3) | nd
Shaikh 2014 25185754 U.S. | Healthy | EPA+DHA | 3.6 g/d [E:D 6:1] | Placebo | 0 | 2 mo | Pill count | 36 | 40.9 | 32 | 45.6 | 2.3 (−3.3, 7.9) | 0.42
Tardivo 2015 25394692 Brazil | Healthy | EPA+DHA | 0.9 g/d [E:D 3:2] | Placebo | 0 | 6 mo | Pill count | 44 | 45.7 | 43 | 44.9 | 0 (−3.5, 3.5) | nd
Vazquez 2014 24462043 Spain | Healthy | EPA+DHA | 0.64 g/d [E:D 1:3] | Placebo | 0 | 2 mo | Assessed by trained dieticians at each visit | 273 | 46.2 | 273 | 46.2 | −0.7 (−2.2, 0.8) | 0.16
Bosch 2012 22686415 Canada | At risk | EPA+DHA | EPA: 0.465 g/d, DHA: 0.375 g/d (Marine oil) [E:D 1.24] | Placebo | 0 | 6 y | FFQ at baseline, 2 years, and end of study (adherence was 88% at the end of study) | 6281 | 46 | 6255 | 46 | 0.1 (−0.7, 0.9) | 0.78
Ballantyne 2012 22819432 U.S. | At risk | EPA+DHA | 4 g/d (Marine oil) | Placebo | 0 | 3 mo | nd | 226 | 37 | 227 | 39 | −5.0 (−8.8, −1.2) | 0.0013
| | EPA+DHA | 2 g/d (Marine oil) | Placebo | 0 | 3 mo | nd | 234 | 38 | 227 | 39 | −2.3 (−5.6, 1.0) | 0.1265
Derosa 2009 19397392 Italy | At risk | EPA+DHA | EPA: 0.9 g/d, DHA: 1.5 g/d (marine oil) | Placebo | 0 | 6 mo | Pill count | 168 | 38.4 | 165 | 39.7 | 3.9 (2.7, 5.1) | nd
Ebrahimi 2009 19593941 Iran | At risk | EPA+DHA | EPA: 0.18, DHA: 0.12 (marine oil) | Placebo | 0 | 6 mo | nd | 47 | 45.6 | 42 | 43.2 | −0.4 (−3.0, 2.2) | nd
Einvik 2010 20389249 Norway | At risk | EPA+DHA | 2.4 g/d (Marine oil) [E:D 1.176:0.84] | Placebo | 0 | 3 y | Pharmacy records/pill count | 70 | 54.8 | 68 | 55.2 | 2.6 (−2.5, 7.8) | ns
| | EPA+DHA + diet | 2.4 g/d (Marine oil) [E:D 1.176:0.84] | Placebo + diet | 0 | 3 y | Pharmacy records/pill count | 69 | 54.8 | 71 | 54.1 | 0.8 (−5.0, 6.5)
Holman 2009 19002433 UK | At risk | EPA+DHA | 2 g/d | Placebo | 0 | 4 mo | Pill count | 371 | nd | 361 | nd | 0.8 (−0.1, 1.6) | 0.082
Jones 2014 24829493 Canada | At risk | EPA+DHA (+ALA) | EPA: 0.1 g/d, DHA: 3.5 g/d, DPA: 1.4 g/d | (ALA) | 0 | 4 wk | Assessed by coordinators | 130 | 47.10 | 130 | 47.10 | 4.1 (1.9, 6.4) | nd
Kastelein 2014 24528690 Europe | At risk | EPA+DHA | EPA: 2.20 g/d, DHA: 0.80 g/d | Placebo | 0 | 12 wk | Pill count | 99 | 28.7 | 98 | 28.7 | 1.1 (−0.5, 2.8) | NS
| | EPA+DHA | EPA: 1.65 g/d, DHA: 0.60 g/d | Placebo | 0 | 12 wk | Pill count | 97 | 28.0 | 98 | 28.7 | 0.5 (−1.1, 2.2) | NS
| | EPA+DHA | EPA: 1.10 g/d, DHA: 0.40 g/d | Placebo | 0 | 12 wk | Pill count | 99 | 27.3 | 98 | 28.7 | 1.5 (−0.2, 3.1) | NS
Liu 2003 Sweden | At risk | EPA+DHA | EPA: 1.7 g/d, DHA: 1.1 g/d | Placebo | 0 | 12 wk | Pill count | 29 | 59.07 | 22 | 59.07 | 2.3 (−7.3, 12.0) | NS
| | EPA+DHA + simvastatin | EPA: 1.7 g/d, DHA: 1.1 g/d | Placebo + simvastatin | 0 | 12 wk | Pill count | 19 | 55.21 | 18 | 64.09 | 2.3 (−9.3, 14.0) | NS
Lungershausen 1994 7852747 Australia | At risk | EPA+DHA | EPA: 1.9 g/d, DHA: 1.5 g/d (marine oil) | Placebo | 0 | 6 wk | Pill count | 42 | 39.8 | 42 | 39.8 | 0.8 (−2.7, 4.3) | 0.664
Maki 2010 20451686 U.S. | At risk | EPA+DHA (+simvastatin) | EPA: 1.86 g/d, DHA: 1.5 g/d | Placebo (+simvastatin) | 0 | 8 wk | Pill count | 122 | 47.3 | 132 | 44.7 | 2.5 (−0.2, 5.2) | <0.001
Maki 2013 23998969 U.S. | At risk | EPA+DHA | 4 g/d total oil (free FA oil) [nd] | Placebo | 0 | 1.5 mo | Biomarker confirmation | 207 | 38.8 | 211 | 38.8 | 0.5 (−1.5, 2.5) | NS
| At risk | EPA+DHA | 2 g/d total oil (free FA oil) [nd] | Placebo | 0 | 1.5 mo | Biomarker confirmation | 209 | 38.7 | 211 | 38.8 | 0.1 (−1.75, 1.95) | NS
Oh, 2014, 25147070 Korea | At risk | EPA+DHA | 4 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 44 | 40 | 42 | 42 | −1.0 (4.1, 2.2)
| | EPA+DHA | 2 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 43 | 43 | 42 | 42 | −2.0 (5.1, 1.2)
| | EPA+DHA | 1 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 44 | 41 | 42 | 42 | 1.0 (2.4, 4.4)
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | 0.85 g/d (Marine oil) | Placebo | 0 | 5 y | Self-reported | 6239 | 50.9 | 6266 | 51.2 | 0.5 (0.03, 1.1) | 0.04
Shaikh 2014 25185754 U.S. | At risk | EPA+DHA | 3.6 g/d [E:D 6:1] | Placebo | 0 | 2 mo | Pill count | 20 | 39.0 | 22 | 39.0 | 1.9 (0.5, 3.3) | 0.0069
Shidfar 2003 12847992 Iran | At risk | ALA + EPA+DHA | EPA 0.5 g/d, DHA 0.31 g/d (suppl) [E:D 1.6] | Placebo | 0 | 2.5 mo | nd | 16 | 39.1 | 19 | 39.2 | −0.3 (−6.8, 6.2)
| | ALA + EPA+DHA + vitamin C | EPA 0.5 g/d, DHA 0.31 g/d (suppl) [E:D 1.6] | Placebo + vitamin C | 0 | 2.5 mo | nd | 16 | 53.3 | 17 | 37.2 | −14.9 (−20.2, −9.6)
Sirtori 1997 9174486 Italy | At risk | EPA+DHA | 2.57 g/d (Marine oil) [E:D 1.45] | Placebo | 0 | 6 mo | nd | 470 | 39.8 | 465 | 39.8 | 0.4 (0.3, 0.5)
Soares 2014 24652053 Brazil | At risk (male) | EPA+DHA (+diet) | 1 g/d (Marine oil) unspecified n-3 FA composition | Placebo | 0 | 3 mo | Not reported | 6 | 43.0 | 6 | 37.3 | 1.7 (−3.9, 7.3) | NS
| At risk (female) | EPA+DHA (+diet) | 1 g/d (Marine oil) unspecified n-3 FA composition | Placebo | 0 | 3 mo | Not reported | 17 | 48.6 | 18 | 48.5 | −0.9 (−3.0, 1.2) | NS
| At risk (male) | EPA+DHA (+diet/exercise) | 1 g/d (Marine oil) unspecified n-3 FA composition | Placebo | 0 | 3 mo | Not reported | 4 | 36.0 | 6 | 34.8 | 9.3 (2.0, 16.6) | NS
| At risk (female) | EPA+DHA (+diet/exercise) | 1 g/d (Marine oil) unspecified n-3 FA composition | Placebo | 0 | 3 mo | Not reported | 17 | 44.1 | 13 | 48.1 | 7.6 (5.2, 10.0) | NS
Tierney 2011 20938439 Europe | At risk | EPA+DHA | EPA 0.26 g/d, DHA 0.19 g/d (suppl) [E:D 1.5] | Placebo | 0 | 3 mo | Pill count and plasma FA | 100 | 42.86 | 106 | 42.08 | 0.77 (−2.439, 3.983) | nd
Vecka 2012 23183517 Czech | At risk | EPA+DHA | 2.58 g/d (Marine oil) [E:D 2.74] | Placebo | 0 | 1.5 mo | nd | 60 | nd | 60 | nd | 1.9 (−25.4, 29.2) [difference of final values] | <0.01
Yokoyama 2007 17398308 Japan | At risk (no previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 8841 | 58.7 | 8862 | 58.3 | −0.4 (−0.9, 0.1) | 0.836
Burr 1989 2571009 UK | CVD | EPA+DHA | 0.357 EPA g/d+nd DPA (suppl: marine oil, diet: fish) | No intervention | 0 | 2 y | Dietary Questionnaire | 982 | 37.1 | 978 | 37.8 | 0.4 (−0.6, 1.4) | NS
Eritsland 1996 8540453 Norway | CVD | EPA+DHA | 3.4 g/d (Marine Oil) | Placebo | 0 | 9 mo | nd | 260 | 40.93 | 251 | 38.6 | 2.0 (0.1, 3.9) | nd
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1192 | 50 | 1236 | 50 | 1.2 (0.1, 2.2) | NS
| | EPA+DHA (+ALA) | 0.4 g/d (Marine oil) [E:D 3:2] | (ALA) | 0 | | | 1212 | 50 | 1197 | 50 | 0.4 (−0.7, 1.5) | nd
Marchioli 2002 11997274 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Marine Oil) | Placebo | 0 | 42 mo | Measured at followup times | 5666 | 41 | 5668 | 41 | 0 (nd) | nd
Nilsen 2001 11451717 Norway | CVD | EPA+DHA | 4 g/d (Marine oil) [E:D 1:2] | Placebo | 0 | Median 1 y | nd | 119 | 41.7 | 120 | 44.8 | 11.9% (nd) | 0.0016
Sacks 1995 7759696 U.S. | CVD | EPA+DHA | EPA: 2.88 g/d DHA: 3.12 g/d (Marine oil) | Placebo | 0 | 2.4 y | Pill count (80% n3, 90% placebo) | 31 | 41 | 28 | 40 | −1.0 (−6.9, 4.9) | nd
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | EPA: 0.386–0.401 g/d DHA: 0.464–0.481 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 | 3.9 y | Measured at clinical exams, patient compliant if drug administered for 80% of days. Both groups had ~30% compliance | 3494 | nd | 3481 | nd | “no differences” | nd
Von Schacky 1999 10189324 Canada | CVD | EPA+DHA | 3.3 g/d | Placebo | 0 | 12 mo | Pill count | 112 | 51.0 | 111 | 50.2 | 3.1 (−1.0, 7.2) | NS
Yokoyama 2007 17398308 Japan | CVD | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level not reported | 485 | 58.3 | 457 | 58.3 | −1.2 (−3.9, 1.6) | 0.882
Marine oil vs Marine oil (miscellaneous)
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | DHA | 3.6 g/d (Ethyl ester) | 2 mo | pill count | 72 | 52.51 | 77 | 51.35 | −1.9 (−3.5, −0.4) | 0.009
Olano-Martin 2010 19748619 UK | Healthy | EPA | 3.3 g/d (Marine oil) | DHA | 3.7 g/d (Marine oil) | 1 mo | nd | 38 | 136.3 | 38 | 139.4 | 1.5 (−3.8, 6.9)
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | 2.3% (−0.9, 5.6)
| At risk | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | 2.1% (−1.1, 5.3)
Marine oil vs Marine oil (doses)
Ras 2014 25122648 Scandinavia | Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | EPA+DHA±DPA | 0.9 g/d EPA+DHA | 1 mo | nd | 62 | 63.3 | 64 | 61.0 | 3.1 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | EPA+DHA±DPA | 1.3 g/d EPA+DHA | 1 mo | nd | 62 | 63.3 | 62 | 63.7 | 0.39 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.3 g/d EPA+DHA | EPA+DHA±DPA | 0.9 g/d EPA+DHA | 1 mo | nd | 62 | 63.7 | 62 | 61.0 | 2.7 (nd) | nd
Caslake 2008 18779276 UK | Healthy | EPA+DHA | 1.8 g/d (Marine oil) | EPA+DHA | 0.7 g/d (Marine oil) | 2 mo | Pill count | 312 | 65.6 | 312 | 65.2 | 0 (−2.5, 2.5) | NS
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (marine oil capsule and margarine) | EPA+DHA | 0.8 g/d (marine oil margarine) | 6 mo | Pill count | 31 | 51.74 | 30 | 52.90 | −1.4 (−5.2, 2.5) | nd
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d( suppl=marine oil) | EPA+DHA | 0.9 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 65.6 | 81 | 65.6 | 3.9 (−1.6, 9.3) | nd
| | EPA+DHA | 1.8 g/d (marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 65.6 | 80 | 61.8 | 0 (−5.5, 5.5) | nd
| | EPA+DHA | 0.9 g/d (marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 81 | 65.6 | 80 | 61.8 | −3.9 (−9.3, 1.6) | nd
Ballantyne 2012 22819432 U.S. | At risk | EPA+DHA | 4 g/d (Marine oil) | EPA+DHA | 2 g/d (Marine oil) | 3 mo | nd | 226 | 37 | 234 | 38 | 0 (nd)
Kastelein 2014 24528690 Europe | At risk | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | 3 mo | Pill count | 99 | 28.7 | 97 | 28.0 | 0.6 (−1.1, 2.3) | nd
| | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | 3 mo | Pill count | 99 | 28.7 | 99 | 27.3 | −0.4 (−2.0, 1.3) | nd
| | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | 3 mo | Pill count | 97 | 28.0 | 99 | 27.3 | −1.0 (−2.6, 0.7) | nd
Oh, 2014, 25147070 Korea | At risk | EPA+DHA | 4 g/d (Marine oil) | EPA+DHA | 2 g/d (Marine oil) | 2 mo | Pill count | 44 | 40 | 43 | 43 | 1 (−2.2, 4.2)
| | EPA+DHA | 4 g/d (Marine oil) | EPA+DHA | 1 g/d (Marine oil) | 2 mo | Pill count | 44 | 40 | 44 | 41 | 0 (3.5, 3.5)
| | EPA+DHA | 2 g/d (Marine oil) | EPA+DHA | 1 g/d (Marine oil) | 2 mo | Pill count | 43 | 43 | 44 | 41 | −3 (6.4, .4)
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 1 y | Pill count | 206 | 45.8 | 210 | 45.7 | 1 (−0.1, −1.2) | nd
Maki 2013 23998969 U.S. | At risk | EPA+DHA | 4 g/d total oil (free FA oil) | EPA+DHA | 4 g/d total oil (free FA oil) | 1.5 mo | Biomarker confirmation | 207 | 38.8 | 209 | 38.7 | 0.4 (−1.67, 2.47) | NS
ALA vs Placebo
Finnegan 2003 12663273 UK | Healthy | ALA | 4.5 g/d (rapeseed oil margarine) | Placebo | 0 | 6 mo | Pill count | 30 | 49.81 | 30 | 52.12 | 0.5 (−3.1, 4.1) | nd
Baxheinrich 2012 22894911 Germany | At risk | ALA | 3.46 g/d (plant oil) | Placebo | ALA: 0.78 g/d | 6 mo | Dietary records | 40 | 52.90 | 41 | 55.21 | 2.3 (−3.0, 7.6) | 0.235
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | Placebo | 0.2 g/d (CornSaff) | 4 wk | Assessed by coordinators | 130 | 47.10 | 130 | 47.10 | 0.1 (−2.3, 2.4) | NS
| | ALA | 1.4 g/d (canolaOleic) | Placebo | 0.2 g/d (CornSaff) | 4 wk | Assessed by coordinators | 130 | 47.10 | 130 | 47.10 | −0.3 (−2.6, 2.1) | NS
Rodriguez-Leyva 2013 24126178 Canada | At risk | ALA | 5.9 g/d (flaxseed) | Placebo | 0 | 1 y | Plasma ALA and enterolignan levels | 43 | 46.3 | 41 | 46.7 | −3.5 (−8.2, 1.2) | 0.13
Kromhout 2010 20929341 Netherlands | CVD | ALA | 2 g/d (plant oil) | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1197 | 49 | 1236 | 49 | −0.8 (−1.8, 0.3) | NS
| | ALA (+EPA+DHA) | 2 g/d (plant oil) | (EPA+DHA) | 0 | | | 1212 | 50 | 1192 | 50 | −1.5 (−2.6, −0.5) | nd
ALA vs ALA (doses)
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | ALA | 1.4 g/d (canolaOleic) | 4 wk | Assessed by coordinators | 130 | 47.10 | 130 | 47.10 | 0.3 (−2, 2.6) | NS
Marine oil vs ALA
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | ALA | 4.5 g/d (rapeseed oil margarine) | 6 mo | Pill count | 31 | 51.74 | 30 | 49.81 | 0.9 (−2.8, 4.7) | nd
| | EPA+DHA | 0.8 g/d (marine oil margarine) | ALA | 4.5 g/d (ALA margarine) | 6 mo | Pill count | 30 | 52.90 | 30 | 49.81 | 2.3 (−1.7, 6.3) | nd
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | ALA | 2 g/d (plant oil) | 40 mo | Audit of unused margarine tubs returned | 1192 | 50 | 1197 | 49 | 1.9 (0.9, 3.0) | nd
SDA vs Placebo
Pieters 2015 25226826 Netherlands | At risk | SDA | 1.2 g/d (suppl) | Placebo | 0 | 1.5 mo | nd | 32 | 52.51 | 32 | 51.43 | 1.16 (−0.39,2.71) | 0.18
SDA vs Marine oil
Kuhnt 2014 24553695 Germany | Healthy | SDA | 2.0 g/d (suppl) | EPA+DHA+DPA | 1.9 g/d (suppl: marine oil) | 2 mo | nd | 20 | 55.21 | 10 | 63.81 | −4.25 (−15.69, 7.19)
Kuhnt 2014 24553695 Germany | Healthy | SDA | 2.0 g/d (suppl) | EPA+DHA+DPA | 1.9 g/d (suppl: marine oil) | 2 mo | nd | 20 | 61.00 | 9 | 74.25 | −2.71 (−18.99,13.58)

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FA = fatty acid(s), FFQ = food frequency questionnaire, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, NS = not significant, PMID = PubMed Identification number, RCT = randomized controlled trial.

#### Total n-3 FA Versus Placebo

Two trials compared total n-3 FA (ALA+EPA+DHA) versus placebo, following 2708 patients for 1 and 40 months; one in people at increased risk for CVD,180 one in people with CVD.119 Baseline HDL-c measurements were 47 and 50 mg/dL. Compliance was measured in both studies, but not reported. The trial in an at risk population found a statistically significant increase in HDL-c with combined ALA 1.2 g/d (canola oil) and EPA+DHA+DPA 5 g/d (3.9 mg/dL; 95% CI 1.5 to 6.2).180 The trial in a CVD population found no significant effect on HDL-c with ALA 2 g/d and EPA+DHA 0.4 g/d.119

#### Marine Oil Versus Placebo

Thirty-four trials evaluated the effect of marine oils versus placebo on HDL-c.46, 51, 53, 56, 58, 61, 62, 67, 70, 75, 76, 80, 94, 96, 97, 99, 103, 105, 107, 115, 116, 119, 120, 128, 146, 156, 160, 166, 173, 177, 179, 180, 194, 195 Doses of EPA+DHA ranged from 0.3 to 6 g/d (median 6 g/d) and followup time ranged from 1 month to 6 years (median 3 months). Across populations, by meta-analysis (Figure 38), the summary net difference in HDL-c with EPA+DHA versus placebo (or equivalent) was a statistically significant, but small, 0.88 mg/dL (95% CI 0.20 to 1.57).

Figure 38 High density lipoprotein cholesterol: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, HDL = high density lipoprotein cholesterol, n-3 FA = omega-3 fatty acid, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure presents meta-analysis results for high density lipoprotein cholesterol in randomized controls that looked at comparisons between marine oil omega-3 fatty acid intake versus a placebo. The meta-analysis was divided into healthy (thirteen cohorts), at risk (29 cohorts) and cardiovascular disease (seven cohorts) populations. Subgroup meta-analysis of the healthy and at risk populations yielded nonsignificant summaries and the cardiovascular disease populations yielded significant summaries of 0.87 (−0.11, 1.84), 0.81 (−0.41, 2.03) and 0.72 (0.16, 1.28), respectively. The overall summary 0.88 (0.20, 1.57), was also significant. Net differences across studies were mostly homogeneous.

##### Healthy Population

Thirteen of the trials of marine oils versus placebo were conducted in healthy populations, comprising data from 3,755 individuals with mean baseline HDL-c ranging from 45 to 57.9 mg/dL and followup duration from 1 to 12 months.55, 61, 75, 80, 94, 97, 107, 128, 136, 173, 174, 187, 189 Two studies compared both EPA (3.3 and 3.8 g/d) and DHA (3.6 and 3.7 g/d), separately, to placebo, one of which evaluated EPA and DHA ethyl esters,61, one of which evaluated EPA- and DHA-enriched oils.107 All other evaluated supplements with both EPA+DHA, with doses ranging from 0.45 to 3.8 g/d. Compliance was verified with pill counts, dietary records, or biomarker confirmation in six of the studies. One trial found significant net increases in HDL-c with marine oil (at two different doses, 0.7 and 1.8 g/d) of 2.3 mg/dL (95% CI 0.2 to 4.5). One study, of DHA 3.6 g/d alone, found a significant net increase in HDL-c (2.7 mg/dL; 95% CI 1.2 to 4.2), but not with EPA 3.8 g/d. The pooled effect size was nonsignificant: 0.87 mg/dL (95% CI −0.11 to 1.84) (Figure 38).187

##### At-Risk-for-CVD Population

Twenty-two of the trials were conducted in populations at increased risk of CVD, comprising data from 48,293 individuals with mean baseline HDL-c ranging from 28.7 to 65.6 mg/dL and followup duration from 1 month to 6 years.46, 53, 58, 76, 80, 90, 99, 103, 105, 115, 116, 120, 146, 156, 160, 166, 177, 179, 180, 187, 194, 195 One study compared DHA (2 g/d) to placebo;80 all other evaluated supplements with both EPA+DHA, with doses ranging from 0.3 to 6 g/d. Compliance was verified with pill counts, dietary records, self-report or biomarker confirmation in 11 of the studies. Thirteen of the 17 trials found no significant effects of EPA+DHA on HDL-c; net change HDL-c varied between 14.9 and 9.3 mg/dL. The pooled effect size was nonsignificant, 0.81 mg/dL (95% CI −0.41 to 2.03) (Figure 38).

##### CVD Population

Nine of the trials were conducted in people with CVD, comprising data from 27,080 individuals with mean baseline HDL-c ranging from 39 to 50.2 mg/dL and followup duration from 9 months to 6 years.48, 51, 56, 62, 67, 70, 90, 96, 119 Doses ranged from 0.36 g/d to 6 g/d; compliance was verified in four of the studies, by pill count or equivalent. Two of the nine trials found significant net increases in HDL-c, but net change HDL-c varied from −1.2 to 3.1 mg/dL. The pooled effect size was a statistically significant, but small, 0.72 mg/dL (95% CI 0.16 to 1.28) (Figure 38).

##### RCT Subgroup Analyses

Eight of the trials compared effects of marine oils in different subgroups of participants; three reported statin vs no statin,46, 99, 156 one with or without vitamin C,76 two men vs women,97, 179 one older vs younger age,97 and one impaired glucose tolerance versus normoglycemia.58 One study found a larger effect of marine oil among participants who were also exercising (men 9.3 mg/dL; women 7.6 mg/dL) than in groups not exercising (men 1.7 mg/dL; women −0.9 mg/dL), although it was unclear whether these differences were significantly different from each other.179 Another study found a small but significantly different effect (P<0.05) of marine oil 2.6 g/d in men with impaired glucose tolerance (0.8 mg/dL) than those with normoglycemia (0.4 mg/dL).58 Other subgroup analyses found no differences in effect between subgroups.

By meta-regression, across studies there were no significant differences in effect (interactions) by HDL-c baseline (P=0.16), n-3 FA dose (P=0.62), followup duration (P=0.24), or population (at risk P=0.29; CVD P=0.82).

#### Marine Oil, Comparison of Different Doses

Eight RCTs directly compared different doses of marine oils (EPA+DHA),75, 97, 136, 151, 161, 169, 177, 194 between 0.9 and 4 g/d. All comparisons were nonsignificant for effect on HDL-c, with estimates of differences ranging from −3.9 mg/dL (95% CI −9.3 to 1.6; 0.9 vs. 0.45 g/d) to 3.9 mg/dL (95% CI −1.6 to 9.3; 1.8 vs. 0.9 g/d).

#### ALA Versus Placebo

Five trials compared ALA versus placebo (or equivalent) in 661 people at increased risk of CVD and one trial of 4837 people with CVD.75, 119, 152, 167, 180 ALA doses ranged from 1.4 to 5.9 g/d and followup ranged from 1 to 40 months. All studies assessed compliance. Effect on HDL-c ranged from −0.3 to 2.3 mg/d, all but one study were statistically nonsignificant.

#### ALA, Comparison of Different Doses

One trial compared ALA 5.9 and 1.4 g/d and found no difference in effect on HDL-c.180

#### Comparison of Different Specific n-3 FA

Two trials directly compared EPA (3.8 or 3.3 g/d) to DHA (3.6 or 3.7 g/d), one of which evaluated EPA and DHA ethyl esters,61 one of which evaluated EPA- and DHA-enriched oils.107 Both found similar (nonsignificant) effects on HDL-c with EPA or DHA. One trial compared two doses of EPA+DHA (3.4 and 1.7 g/d) to EPA 1.8 g/d (all ethyl esters),169 with no differences between marine oil formulations. Two trials compared EPA+DHA to ALA. One compared two doses of EPA+DHA (1.7 and 0.8 g/d) to ALA 4.5 g/d;75 both comparisons were nonsignificant with similar net differences (1.5 and 2.3 mg/dL). The second trial compared EPA+DHA 0.2 g/d to ALA 2 g/d; the study did not report a significant difference, but a calculated net difference was statistically significant favoring EPA+DHA (net difference 1.9 mg/dL; 95% CI 0.9 to 3.0).119

#### SDA Versus Placebo

Pieters 2015 compared 1.2 g/d SDA to placebo in 32 patients at risk for CVD. At 1.5 month followup, no significant differences in change in HDL-c were found.188

#### SDA Versus Marine Oil

Kuhnt 2014 compared 2.0 g/d SDA and 1.9 g/d EPA+DHA+DPA in 59 healthy people (broken into cohorts based on body mass index and age). At 2 month followup, no significant differences in change in HDL-c were found.178

### Observational Studies

Observational studies did not evaluate HDL-c.

## Triglycerides

### Randomized Controlled Trials

Forty-six RCTs provided data on effect of n-3 FA on Tg (Table 43).46, 51, 53, 56, 58, 61, 62, 67, 70, 75, 76, 90, 94, 96, 97, 99, 103, 105, 107, 115, 116, 119–121, 125, 128, 136, 146, 150–152, 156, 160, 167, 169, 173, 174, 177, 178, 180, 184, 187–189, 194 Compared with other outcomes, a relatively large number of trials, 11, but still a minority, reported Tg among their primary outcome (Brinton 2013, Caslake 2008, Damsgaard 2008, Kastelein 2014, Lungershausen 1994, Pieters 2015, Ras 2014, Rauch 2010, Shidfar 2003, Sirtori 1997, Vazquez 2014); however, Rauch 2010 reported Tg to be a secondary outcome in the ClinicalTrials.gov registry.

Table 43 Triglycerides: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int N | Int Baseline, mg/dL | Ctrl N | Ctrl Baseline, mg/dL | Net Chg, mg/dL (95% CI) | Reported P value
Total n-3 FA vs Placebo
Jones 2014 24829493 Canada | At risk | ALA + EPA+DHA | ALA: 1.2 g/d, EPA: 0.1 g/d, DHA: 3.5 g/d, DPA: 1.4 g/d (canola+DHA) | Placebo | 0.2 g/d (CornSaff) | 4 wk | Assessed by coordinators | 130 | 147.8 | 130 | 147.8 | −22.5 (−37.5, −7.6) | <0.05
Kromhout 2010 20929341 Netherlands | CVD | ALA + EPA+DHA | 0.4 g/d EPA+DHA; 2 g/d ALA (Marine oil, plant oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1212 | 145 | 1236 | 150 | −8 (−16.6, 0.7)
Marine oil vs Placebo
Ras 2014 25122648 Scandinavia | Healthy | EPA+DHA±DPA | 0.9 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 64 | 93.0 | 64 | 94.0 | −2.5 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.3 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 62 | 91.2 | 64 | 94.0 | −4.8 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | Placebo | 0 | 1 mo | nd | 62 | 94.0 | 64 | 94.0 | −10.7 (nd) | nd
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | Placebo | 0 | 2 mo | pill count | 75 | 108.85 | 77 | 107.96 | −23 (−33.5, −12.6) | 0.0001
| | DHA | 3.6 g/d (Ethyl ester) | Placebo | 0 | 2 mo | pill count | 72 | 109.73 | 77 | 107.96 | −29.2 (−38.4, −20.0) | 0.0001
Olano-Martin 2010 19748619 UK | Healthy | EPA | 3.3 g/d (Marine oil) | Placebo | 0 | 1 mo | nd | 38 | 143.4 | 38 | 123.0 | −41.6 (−69.9, −13.3)
| | DHA | 3.7 g/d (Marine oil) | Placebo | 0 | 1 mo | nd | 38 | 132.7 | 38 | 123.0 | −27.4 (−45.3, −9.5)
Carrepeiro 2011 21561620 Brazil | Healthy | EPA+DHA | 2.4 g/d (Marine oil) | Placebo | 0 | 6 mo | nd | 23 | 101.2 | 23 | 112.9 | −1.8 (−3.8, 0.2) | 0.077
| | EPA+DHA + Statin | 2.4 g/d (Marine oil) | Placebo + Statin | 0 | 6 mo | nd | 20 | 140.1 | 20 | 120.8 | −2.0 (−4.0, 0) | 0.054
Caslake 2008 18779276 UK | Healthy | EPA+DHA | 1.8 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 312 | 113.3 | 312 | 112.4 | −1.4 (−10.8, 7.9) | <0.017
| | EPA+DHA | 0.7 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 312 | 110.6 | 312 | 112.4 | −8.0 (−17.3, 1.3) | <0.017
Damsgaard 2008 18492834 Scandinavia | Healthy | EPA+DHA + high LA | 3.1 g/d (Marine oil) [E:D 1.64] | Placebo + high LA | 0 | 2 mo | nd | 17 | 71.7 | 16 | 79.6 | −7.3 (−14.3, −0.4)
| | EPA+DHA + low LA | 3.1 g/d (Marine oil) [E:D 1.64] | Placebo + low LA | 0 | 2 mo | nd | 14 | 113.3 | 17 | 89.4 | −18.1 (−27.8, −8.5)
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | Placebo | 0 | 6 mo | Pill count | 31 | 141.59 | 30 | 149.56 | −5.7 (−24.0, 12.7) | nd
| | EPA+DHA | 0.8 g/d (marine oil margarine) | Placebo | 0 | 6 mo | Pill count | 30 | 146.02 | 30 | 149.56 | 7.7 (−3.6, 19.0) | nd
Grieger 2014 24454276 Australia | Healthy | EPA+DHA | 0.8 g/d (fish diet) | Placebo | EPA: 0.017 g/d, DHA: 0.004 g/d (red meat diet) | 8 wk | Weighed food records | 43 | 97.35 | 37 | 123.89 | 0 (−24.5, 24.5) | nd
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 97.3 | 71 | 102.6 | −15.0 (−27.4, −2.7) | nd
| | EPA+DHA | 0.9 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 81 | 100 | 71 | 102.6 | −3.5 (−16.5, 9.4) | nd
| | EPA+DHA | 0.45 g/d ( suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 100.9 | 71 | 102.6 | −2.7 (−15.8, 10.5) | nd
Shaikh 2014 25185754 U.S. | Healthy | EPA+DHA | 3.6 g/d [E:D 6:1] | Placebo | 0 | 2 mo | Pill count | 36 | 154.9 | 32 | 131.0 | −28.3 (−63.0, 6.4) | 0.11
Tardivo 2015 25394692 Brazil | Healthy | EPA+DHA | 0.9 g/d [E:D 3:2] | Placebo | 0 | 6 mo | Pill count | 44 | 192.5 | 43 | 187.6 | −26 (−50.9, −1.1) | nd
Vazquez 2014 24462043 Spain | Healthy | EPA+DHA | 0.64 g/d [E:D 1:3] | Placebo | 0 | 2 mo | Assessed by trained dieticians at each visit | 273 | 170.6 | 273 | 170.6 | −4.0 (−15.1, 7.2) | 0.368
Bosch 2012 22686415 Canada | At risk | EPA+DHA | EPA: 0.465 g/d, DHA: 0.375 g/d (Marine oil) [E:D 1.24] | Placebo | 0 | 6 y | FFQ at baseline, 2 y, and end of study (adherence 88% at end of study) | 6281 | 142 | 6255 | 140 | −14.5 (−22.8, −6.2) | <0.001
Ballantyne 2012 22819432 U.S. | At risk | EPA+DHA | 4 g/d (marine oil) | Placebo | 0 | 3 mo | nd | 226 | 264.8 | 227 | 259 | −23.2 (−34.9, −11.5) | <0.0001
| | EPA+DHA | 2 g/d (marine oil) | Placebo | 0 | 3 mo | nd | 234 | 254 | 227 | 259 | −9.8 (−17.3, −2.3) | 0.0005
Derosa 2009 19397392 Italy | At risk | EPA+DHA | EPA: 0.9 g/d, DHA: 1.5 g/d (marine oil) | Placebo | 0 | 6 mo | Pill count | 168 | 182.6 | 165 | 189.3 | −59.2 (−67.4, −51.0) | nd
Earnest 2012 22811376 U.S. | At risk | EPA+DHA | 2 g/d EPA+DHA (Marine oil) [E:D ratio 0.76:0.44] | Placebo | 0 | 3 mo | Pill count | 21 | 111 | 23 | 111 | −27.7 (−51.4, −4.0)
| | EPA+DHA + multivitamin | 2 g/d EPA+DHA + (Marine oil) [E:D ratio 0.76:0.44] | Placebo + multivitamin | 0 | 3 mo | Pill count | 25 | 116 | 23 | 113 | −75.7 (−98.5, −52.9)
Ebrahimi 2009 19593941 Iran | At risk | EPA+DHA | EPA: 0.18, DHA: 0.12 (marine oil) | Placebo | 0 | 6 mo | nd | 47 | 155.8 | 42 | 145.1 | −7.1 (nd) | nd
Einvik 2010 20389249 Norway | At risk | EPA+DHA +/− diet | 2.4 g/d EPA+DHA (Marine oil) [E:D ratio 0.66:1.1] | Placebo +/minus; diet | 0 | 3 y | Pharmacy records/pill count | 282 | 141.6 | 281 | 132.7 | −35.4 (−97.5, 26.7)
| At risk | EPA+DHA | 2.4 g/d EPA+DHA (Marine oil) [E:D ratio 0.66:1.1] | Placebo | 0 | 3 y | Pharmacy records/pill count | 70 | 152.2 | 68 | 151.3 | −15.0 (−41.3, 11.2) | --
| | EPA+DHA + diet | 2.4 g/d EPA+DHA (Marine oil) [E:D ratio 0.66:1.1] | Placebo + diet | 0 | 3 y | Pharmacy records/pill count | 69 | 154.9 | 71 | 154.0 | −20.4 (−44.3, 3.6)
Holman 2009 19002433 UK | At risk | EPA+DHA | 2 g/d | Placebo | 0 | 4 mo | Pill count | 371 | 132.7 | 361 | 137.2 | −6.2 (−15.6, 3.2) | 0.003
Jones 2014 24829493 Canada | At risk | EPA+DHA (+ALA) | EPA: 0.1 g/d, DHA: 3.5 g/d, DPA: 1.4 g/d (canola+DHA) | (ALA) | 0 | 4 wk | Assessed by coordinators | 130 | 147.8 | 130 | 147.8 | −28 (−42.6, −13.4) | <0.05
Liu 2003 Sweden | At risk | EPA+DHA | EPA: 1.7 g/d, DHA: 1.1 g/d | Placebo | 0 | 12 wk | Pill count | 29 | 146.90 | 22 | 142.48 | −39.8 (−76.4, −3.3) | <0.05
| | EPA+DHA + simvastatin | EPA: 1.7 g/d, DHA: 1.1 g/d | Placebo + simvastatin | 0 | 12 wk | Pill count | 19 | 154.87 | 18 | 136.28 | −35.4 (−79.6, 8.8) | <0.05
Lungershausen 1994 7852747 Australia | At risk | EPA+DHA | EPA: 1.9 g/d, DHA: 1.5 g/d (marine oil) | Placebo | 0 | 6 wk | Pill count | 42 | 141.59 | 42 | 141.59 | −28.3 (−54.8, −1.8) | 0.05
Kastelein 2014 24528690 Europe | At risk | EPA+DHA | EPA: 2.20 g/d, DHA: 0.80 g/d | Placebo | 0 | 12 wk | Pill count | 99 | 655 | 98 | 682 | −173.1 (−250.3, −95.8) | <0.001
| | EPA+DHA | EPA: 1.65 g/d, DHA: 0.60 g/d | Placebo | 0 | 12 wk | Pill count | 97 | 728 | 98 | 682 | −156.3 (−238.8, −73.8) | <0.01
| | EPA+DHA | EPA: 1.10 g/d, DHA: 0.40 g/d | Placebo | 0 | 12 wk | Pill count | 99 | 717 | 98 | 682 | −156.4 (−238.1, −74.6) | <0.01
Maki 2010 20451686 U.S. | At risk | EPA+DHA (+simvastatin) | EPA: 1.86 g/d, DHA: 1.5 g/d | Placebo (+simvastatin) | 0 | 8 wk | Pill count | 122 | 282 | 132 | 286.7 | −68.8 (−89.3, −48.3) | <0.001
Maki 2013 23998969 U.S. | At risk | EPA+DHA | 4 g/d total oil (free FA oil) [nd] | Placebo | 0 | 1.5 mo | Biomarker confirmation | 207 | 287 | 211 | 280 | −42 (−59.3, −24.7) | <0.001
| At risk | EPA+DHA | 2 g/d total oil (free FA oil) [nd] | Placebo | 0 | 1.5 mo | Biomarker confirmation | 209 | 284 | 211 | 280 | −28 (−44.0, −12.0) | <0.001
Oh, 2014, 25147070 Korea | At risk | EPA+DHA | 4 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 44 | 287 | 42 | 281 | −62.0 (−102.5, −21.5)
| | EPA+DHA | 2 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 43 | 267 | 42 | 281 | −30.0 (−73.1, 13.1)
| | EPA+DHA | 1 g/d (Marine oil) | Placebo | 0 | 2 mo | Pill count | 44 | 286 | 42 | 281 | −23.0 (−60.6, 14.6)
Roncaglioni 2013 23656645 Italy | At risk | EPA+DHA | 0.85 g/d (Marine oil) | Placebo | 0 | 5 y | Self-reported | 6239 | 150 | 6266 | 150 | −8.1 (−11.6, −4.5) | <0.0001
Shaikh 2014 25185754 U.S. | At risk | EPA+DHA | 3.6 g/d [E:D 6:1] | Placebo | 0 | 2 mo | Pill count | 20 | 274.3 | 22 | 263.7 | −95.6 (−149.4, −41.8) | 0.0005
Shidfar 2003 12847992 Iran | At risk | EPA+DHA | EPA 0.5 g/d, DHA 0.31 g/d (suppl) [E:D 1.6] | Placebo | 0 | 2.5 mo | nd | 16 | 304 | 19 | 311.5 | −109.1 (−176.9, −41.4)
| | EPA+DHA + vitamin C | EPA 0.5 g/d, DHA 0.31 g/d (suppl) [E:D 1.6] | Placebo + vitamin C | 0 | 2.5 mo | nd | 16 | 297.3 | 17 | 315 | 15.2 (−43.9, 74.3)
Sirtori 1997 9174486 Italy | At risk | EPA+DHA | 2.57 g/d (Marine oil) [E:D 1.45] | Placebo | 0 | 6 mo | nd | 470 | 293.8 | 465 | 297.3 | −37.2 (−51.0, −23.3)
Tierney 2011 20938439 Europe | At risk | EPA+DHA | EPA 0.26 g/d, DHA 0.19 g/d (suppl) [E:D 1.5] | Placebo | 0 | 3 mo | Pill count and plasma FA | 100 | 148.67 | 106 | 147.79 | −19.47 (−44.664, 5.726) | nd
Vecka 2012 23183517 Czech | At risk | EPA+DHA | 2.58 g/d (Marine oil) [E:D 2.74] | Placebo | 0 | 1.5 mo | nd | 60 | nd | 60 | nd | −82.3 (−852.6, 688) [difference of final values] | <0.001
Yokoyama 2007 17398308 Japan | At risk (no previous CHD) | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level was not reported | 8841 | 153.1 | 8862 | 153.1 | −8.9 (−11.0, −6.7) | <0.0001
Eritsland 1996 8540453 Norway | CVD | EPA+DHA | 3.4 g/d (Marine oil) | Placebo | 0 | 9 mo | nd | 260 | 171.62 | 251 | 184.96 | −32.0 (−48.4, −15.6) | <0.001
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1192 | 144 | 1236 | 150 | −2.7 (−13.8, 8.5)
| | EPA+DHA (+ALA) | 0.4 g/d (Marine oil) [E:D 3:2] | (ALA) | 0 | | | 1212 | 145 | 1197 | 146 | −2.7 (−11.3, 6.0)
Marchioli 2002 11997274 Italy | CVD | EPA+DHA | 0.850–0.882 g/d (Marine Oil) | Placebo | 0 | 42 mo | Measured at followup times | 5666 | 162 | 5668 | 162 | −10 (nd)
Nilsen 2001 11451717 Norway | CVD | EPA+DHA | 4 g/d (Marine oil) [E:D 1:2] | Placebo | 0 | Median 1.5 y | nd | 120 | 145.1 | 121 | 137.2 | −37.42% (nd) | nd
Nodari 2011 21215550 Italy | CVD | EPA+DHA | 2 g/d EPA+DHA (Marine oil) [E:D ratio 0.9:1.5] | Placebo | 0 | 1 y | Pill count | 67 | 149 | 66 | 154 | −7.0 (−29.0, 15.0) | --
Rauch 2010 21060071 Germany | CVD | EPA+DHA | 1 g/d (Marine oil) [E:D ratio 0.460:0.380] | Placebo | 0 | 1 y | Pill count | 1925 | Not reported | 1893 | Not reported | −5 (nd) | <0.01
Sacks 1995 7759696 U.S. | CVD | EPA+DHA | EPA: 2.88 g/d DHA: 3.12 g/d (Marine oil) | Placebo | 0 | 2.4 y | Pill count (80% n3, 90% placebo) | 31 | 128 | 28 | 137 | −33.0 (−66.6, 0.6)
Tavazzi 2008 18757090 Italy | CVD | EPA+DHA | EPA: 0.386–0.401 g/d DHA: 0.464–0.481 g/d (Ethyl esters) [E:D 0.83] | Placebo | 0 | 3.9 y | Measured at clinical exams, patient was compliant if drug administered for 80% of days. Both groups had ~30% compliance | 3494 | 1.42(median) | 3481 | nd | −7.1 (nd) | <0.0001
Von Schacky 1999 10189324 Canada | CVD | EPA+DHA | 3.3 g/d | Placebo | 0 | 12 mo | Pill count | 112 | 194.7 | 111 | 191.2 | −49.6 (−81.4, −17.7) | <0.01
Yokoyama 2007 17398308 Japan | CVD | EPA+Statin | 1.8 g/d (Ethyl ester) | Statin | 0 | 4.6 y | Local physicians monitored but compliance level not reported | 485 | 159.3 | 457 | 159.3 | −15.1 (−23.7, −6.4) | <0.001
Marine oil vs Marine oil (dose)
Ras 2014 25122648 Scandinavia | Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | EPA+DHA±DPA | 0.9 g/d EPA+DHA | 1 mo | nd | 62 | 94.0 | 64 | 93.0 | −8.3 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.8 g/d EPA+DHA | EPA+DHA±DPA | 1.3 g/d EPA+DHA | 1 mo | nd | 62 | 94.0 | 62 | 91.2 | −5.9 (nd) | nd
| Healthy | EPA+DHA±DPA | 1.3 g/d EPA+DHA | EPA+DHA±DPA | 0.9 g/d EPA+DHA | 1 mo | nd | 62 | 91.2 | 62 | 93.0 | −2.3 (nd) | nd
Caslake 2008 18779276 UK | Healthy | EPA+DHA | 1.8 g/d (Marine oil) | EPA+DHA | 0.7 g/d (Marine oil) | 2 mo | Pill count | 312 | 113.3 | 312 | 110.6 | 6.2 (−2.6, 15.0) | NS
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | 6 mo | 0.8 g/d (marine oil margarine) | EPA+DHA | Pill count | 31 | 141.59 | 30 | 146.02 | −13.4 (−30.8, 4.0) | nd
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d( suppl=marine oil) | EPA+DHA | 0.9 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 97.3 | 81 | 100 | −11.5 (−24.2, 1.2) | nd
| | EPA+DHA | 1.8 g/d (marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 97.3 | 80 | 100.9 | −12.4 (−88.4, 63.7) | nd
| | EPA+DHA | 0.9 g/d (marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 81 | 100 | 80 | 100.9 | −0.9 (−77.0, 75.3) | nd
Ballantyne 2012 22819432 23835245 U.S. | At risk | EPA+DHA | 4 g/d (marine oil) | EPA+DHA | 2 g/d (Marine oil) | 3 mo | nd | 226 | 264.8 | 234 | 254 | −32.1 (nd)
Kastelein 2014 24528690 Europe | At risk | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | 3 mo | nd | 99 | 655 | 99 | 728 | −16.8 (−86.1, 52.6) | nd
| | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | 3 mo | nd | 99 | 655 | 99 | 717 | −16.7 (−85.1, 51.8) | nd
| | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | 3 mo | nd | 97 | 728 | 99 | 717 | 0.1 (−74.3, 74.4) | nd
Oh, 2014, 25147070 Korea | At risk | EPA+DHA | 4 g/d (Marine oil) | EPA+DHA | 2 g/d (Marine oil) | 2 mo | Pill count | 44 | 287 | 43 | 267 | −32 (−77.2, 13.2)
| | EPA+DHA | 4 g/d (Marine oil) | EPA+DHA | 1 g/d (Marine oil) | 2 mo | Pill count | 44 | 287 | 44 | 286 | −39 (−79.1, 1.1)
| | EPA+DHA | 2 g/d (Marine oil) | EPA+DHA | 1 g/d (Marine oil) | 2 mo | Pill count | 43 | 267 | 44 | 286 | −7.0 (−49.7, 35.7)
Tatsuno 2013 23725919 Japan | At Risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 12 wk | Pill count | 210 | 277.5 | 206 | 269 | −37.2 (−53.9, −20.5) | nd
| At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 1 y | nd | 170 | nd | 165 | nd | −11.6% (−17.9, −5.3)
Maki 2013 23998969 U.S. | At risk | EPA+DHA | 4 g/d total oil (free FA oil) [nd] | EPA+DHA | 4 g/d total oil (free FA oil) [nd] | 1.5 mo | Biomarker confirmation | 207 | 287 | 209 | 284 | −14 (−31.3, 3.3) | nd
Marine oil vs Marine oil (miscellaneous)
Olano-Martin 2010 19748619 UK | Healthy | EPA | 3.3 g/d (Marine oil) | DHA | 3.7 g/d (Marine oil) | 1 mo | nd | 38 | 143.4 | 38 | 132.7 | 14.2 (−14.1, 42.5)
Grimsgaard 1998 9665096 Norway | Healthy | EPA | 3.8 g/d (Ethyl ester) | DHA | 3.6 g/d (Ethyl ester) | 2 mo | pill count | 77 | 108.85 | 72 | 109.73 | 6.2 (−4.0, 16.4) | 0.14
Tatsuno 2013 23725919 Japan | At Risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 12 wk | Pill count | 210 | 277.5 | 195 | 271.8 | −35 (−53.3, −16.7) | nd
| | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 12 wk | Pill count | 206 | 269 | 195 | 271.8 | 1.7 (−15.7, 19.1) | nd
| | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | −13.5% (−20.9, −6.0)
| | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | −1.9% (−9.6, 5.8)
ALA vs Placebo
Finnegan 2003 12663273 UK | Healthy | ALA | 4.5 g/d (rapeseed oil margarine) | Placebo | 0 | 6 mo | Pill count | 30 | 146.90 | 30 | 149.56 | 22.0 (2.1, 41.9) | NS
Baxheinrich 2012 22894911 Germany | At risk | ALA | 3.46 g/d (plant oil) | Placebo | ALA: 0.78 g/d | 6 mo | Dietary records | 40 | 171.68 | 41 | 145.13 | −22.1 (−59.0, 14.8) | 0.020
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | Placebo | 0.2 g/d (CornSaff) | 4 wk | Assessed by coordinators | 130 | 147.8 | 130 | 147.8 | 5.4 (−9.6, 20.3) | NS
| | | 1.4 g/d (canolaOleic) | Placebo | 0.2 g/d (CornSaff) | 4 wk | Assessed by coordinators | 130 | 147.8 | 130 | 147.8 | 5.5 (−9.4, 20.4) | NS
Rodriguez-Leyva 2013 24126178 Canada | At risk | ALA | 5.9 g/d (flaxseed) | Placebo | 0 | 1 y | Plasma ALA and enterolignan levels | 43 | 141.6 | 41 | 150.4 | 26.5 (−4.4, 57.5) | 0.07
Kromhout 2010 20929341 Netherlands | CVD | ALA | 2 g/d (plant oil) | Placebo | 0 | 40 mo | Audit of unused margarine tubs returned | 1197 | 146 | 1236 | 150 | −5.3 (−15.1, 4.5)
| | ALA (+EPA+DHA) | 2 g/d (plant oil) | (EPA+DHA) | 0 | | | 1212 | 145 | 1192 | 144 | −5.3 (−15.4, 4.8)
ALA vs ALA (doses)
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (canola) | ALA | 1.4 g/d (canolaOleic) | 4 wk | Assessed by coordinators | 130 | 147.8 | 130 | 147.8 | −0.1 (−14.7, 14.5) | NS
EPA+DHA vs ALA
Finnegan 2003 12663273 UK | Healthy | EPA+DHA | 1.7 g/d (marine oil capsule and marine oil margarine) | ALA | 4.5 g/d (rapeseed oil margarine) | 6 mo | Pill count | 31 | 141.59 | 30 | 146.90 | −27.7 (−48.7, −6.6) | nd
| | EPA+DHA | 0.8 g/d (marine oil margarine) | ALA | 4.5 g/d (ALA margarine) | 6 mo | Pill count | 30 | 146.02 | 30 | 146.90 | −14.3 (−33.3, 4.8) | nd
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 3:2] | ALA | 2 g/d (plant oil) | 40 mo | Audit of unused margarine tubs returned | 1192 | 144 | 1197 | 146 | 2.7 (−8.5, 13.8)
SDA vs Placebo
Pieters 2015 25226826 Netherlands | At risk | SDA | 1.2 g/d (suppl) | Placebo | 0 | 1.5 mo | nd | 32 | 120.35 | 32 | 110.53 | 9.73 (−4.73, 24.19) | 0.21
SDA vs Marine oil
Kuhnt 2014 24553695 Germany | Healthy | SDA | 2.0 g/d (suppl) | EPA+DHA+DPA | 1.9 g/d (suppl: marine oil) | 2 mo | nd | 20 | 78.76 | 10 | 68.14 | −1.75 (−17.59, 14.08)
Kuhnt 2014 24553695 Germany | Healthy | SDA | 2.0 g/d (suppl) | EPA+DHA+DPA | 1.9 g/d (suppl: marine oil) | 2 mo | nd | 20 | 100.89 | 9 | 79.65 | 13.16 (−10.11, 36.42)

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FA = fatty acid(s), FFQ = food frequency questionnaire, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, NS = not significant, PMID = PubMed Identification number, RCT = randomized controlled trial, SDA = stearidonic acid.

#### Total n-3 FA Versus Placebo

Two trials compared total n-3 FA (ALA+EPA+DHA) versus placebo, following 2708 patients for 1 and 40 months; one in people at increased risk for CVD,180 one in people with CVD.119 Baseline Tg measurements were 147.8 and 150 mg/dL. Compliance was measured in both studies, but not reported. The trial in an at risk population found a statistically significant decrease in Tg with combined ALA 1.2 g/d (canola oil) and EPA+DHA+DPA 5 g/d (−27 mg/dL; 95% CI −37.5 to −7.6).180 The trial in a CVD population found no significant effect on Tg with ALA 2 g/d and EPA+DHA 0.4 g/d.119

#### Marine Oil Versus Placebo

Forty-one trials evaluated the effect of marine oils versus placebo on Tg.46, 51, 53, 56, 58, 61, 62, 67, 70, 75, 76, 90, 94, 96, 97, 99, 103, 105, 107, 115, 116, 119–121, 125, 128, 136, 146, 150, 151, 156, 160, 166, 173, 174, 177, 180, 187, 189, 194 Doses of EPA+DHA±DPA ranged from 0.3 to 6 g/d (median 2.4 g/d) and followup time ranged from 1 month to 6 years (median 3 months). All but two studies found net decreases in Tg with EPA+DHA. Across populations, the summary net difference in Tg with EPA+DHA versus placebo (or equivalent) was a statistically significant −24 mg/dL (95% CI −31 to −18) among studies reporting sufficient data to be included in meta-analysis. As will be described below, net change Tg varied across studies by mean baseline Tg and, possibly, by EPA+DHA dose, but did not vary significantly by population (Figure 39).

Figure 39 Triglycerides: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid

This figure presents meta-analysis results for triglycerides in randomized controls that looked at comparisons between marine oil omega-3 fatty acid intake versus a placebo. The meta-analysis was divided into healthy (thirteen cohorts), at risk (24 cohorts) and cardiovascular disease (seven cohorts) populations. Subgroup meta-analysis of the healthy, at risk and cardiovascular disease populations yielded significant summaries of −13.16 (−20.16, −6.17), −45.08 (−61.19, −28.98) and −20.11 (−33.48, −6.73), respectively. The overall summary −24.41 (−31.05, −17.77), was also significant. Net differences across studies were mostly homogeneous.

##### Healthy Population

Fourteen of the trials were conducted in 3,560 generally healthy participants.61, 75, 94, 97, 103, 107, 128, 136, 146, 151, 173, 174, 187, 189 Two of the trials evaluated both purified EPA and DHA separately (3.3 to 3.8 g/d); the rest evaluated EPA+DHA (0.45 to 3.1 g/d). Followup ranged from 1 to 12 months. Four studies evaluated compliance with pill count or weighed food records. Baseline Tg ranged from 80 to 188 mg/dL. Net difference between marine oil and placebo varied widely across studies from −42 to 7.7 mg/dL. The pooled effect size was a significant −13.2 mg/dL (95% CI −20.2 to −6.2) (Figure 39).

##### At-Risk-for-CVD Population

Twenty-three trials compared EPA+DHA to placebo (or equivalent) in 48,648 people at increased risk of CVD.46, 53, 56, 58, 76, 90, 99, 103, 105, 115, 116, 119, 120, 146, 150, 156, 160, 166, 177, 180, 187, 194, 195 EPA+DHA dosages ranged from 0.3 to 5 g/d and followup ranged from 1 month to 6 years. Eleven of the studies measured compliance by pill count, coordinator “assessment,” or self-report. Mean baseline Tg ranged from 111 to 315 mg/d in 15 of the trials, was 682 mg/d in one study that included only people with severe hypertriglyceridemia (≥500 mg/d),177 and was not reported in four trials. Excluding the trial of severe hypertriglyceridemia, net change Tg with EPA+DHA ranged from −109 (difference between final values) to 15 mg/dL. The study of people with hypertriglyceridemia found large, significant net reductions of Tg with EPA+DHA doses of 1.5, 2.25, and 3 g/d of −156 mg/d (lower two doses) and −173 mg/d (3 g/d). The pooled effect size (with the hypertriglyceridemia study) was a significant −45.1 mg/dL (95% CI −61.2 to −29.0) (Figure 39); without Kastelein, the pooled net difference was identical.

##### CVD Population

Ten trials compared EPA+DHA to placebo in 29,018 people with CVD.51, 56, 62, 67, 70, 90, 96, 119, 121, 125 EPA+DHA dosages ranged from 0.4 to 6 g/d and followup ranged from 9 months to 4.6 y. All but one study measured, but few reported, compliance. Mean baseline Tg ranged from 137 to 191 mg/d when reported. Across trials, net change Tg with EPA+DHA ranged from −50 to −3 mg/dL. The pooled effect size was a significant −20.1 mg/dL (95% CI −33.5 to −6.7) (Figure 39).

##### RCT Subgroup Analyses

The four studies that examined subgroup effects of EPA+DHA on Tg based on statin use all found no significant interaction between marine oil and statins (Carrepeiro 2011, Holman 2009, Liu 2003, Vecka 2012).46, 99, 128, 156 In one study each, no significant differences in effect were seen in those on high or low linoleic acid diets (Damsgaard 2008),94 in those receiving or not general diet counseling (Einvik 2010),115 or in older or younger age groups (Caslake 2008).97 One study found a significantly larger effect in people also taking a multivitamin (−76 mg/dL) than in those without the multivitamin (−28 mg/dL; P interaction <0.05), but Tg increased in only the group taking multivitamins and placebo (Earnest 2012).150 In contrast, one found a net increase in Tg concentration in people also taking vitamin C (15 mg/dL, due to a smaller decrease in Tg concentration than in the vitamin C alone group) and a large net decrease in people not taking vitamin C (−109 mg/dL), but this difference in effect was not reported to be significantly different.76 One study examined gender effect and found that men on higher dose EPA+DHA (1.8 g/d) had a larger effect than women (P<0.038; difference not reported), but similar effects at lower dose (0.7 g/d) (Caslake 2008).97 One study found no difference in effect of EPA between people with either impaired glucose tolerance or noninsulin dependent diabetes or normoglycemia (Sirtori 1997), but among those with diabetes, those with lower HDL-c (≤35 mg/dL) had a greater effect of EPA+DHA on Tg (−23.3%) than those with higher HDL-c (−16.9%; P interaction <0.05).58 This difference in effect by HDL-c levels, however, was not seen among those with normoglycemia. One study of people with diabetes (Brinton 2013) found that with higher dose EPA+DHA (4 g/d) there was no difference in change in Tg by hemoglobin A1c level, but at 2 g/d, those with higher A1c levels (>6.8%) had a smaller effect that was nonsignificant (−5% net change) compared to those with lower A1c levels (−15%, P<0.01), although the study did not analyze whether the interaction was significant.195

By meta-regression, across studies there were no significant differences in effect (interactions) by population (at risk P=0.30; CVD P=0.52) or followup duration (P=0.49). However, both mean baseline Tg level and EPA+DHA dose across studies were significantly associated with net change Tg. The primary metaregression was conducted excluding an outlier study (Kastelein 2014) of people with severe hypertriglyceridemia (Tg >500 mg/dL at baseline), who were found to have large net changes with EPA+DHA 3, 2.25, and 1.5 g/d.177 Analyses with this study, however, yielded similar results. Controlling for both variables, each increase in mean baseline Tg level by 1 mg/dL was associated with a greater net change Tg of −0.15 mg/dL (95% CI −0.22 to −0.08; P<0.0001) (Figure 40). Each increase of EPA+DHA dose by 1 g/d was also associated with a greater net change Tg of −5.9 mg/dL (95% CI −9.9 to −2.0; P=0.003) (Figure 41). By spline analysis of the meta-regression, there was no clear inflection point where the association between dose and net change Tg substantially changed.

Figure 40 Metaregression of effect of EPA+DHA on net change Tg, by mean baseline Tg

Association of mean baseline Tg (tgbaseline) in mg/dL on net change Tg (tgnetdiff) in mg/dL.

Abbreviations: DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, n-3 = omega-3 fatty acids, Tg = triglycerides.

This figure presents meta-regression results of effect of EPA+DHA on net change in triglycerides, using mean baseline triglyceride measurements as a predictor for the model. This graph displays a negative association of mean baseline triglycerides in mg/dL on net change triglycerides in mg/dL.

Figure 41 Metaregression of effect of EPA+DHA on net change Tg, by EPA+DHA dose

Association of EPA+DHA dose (nd_dose) in g/d on net change Tg (tgnetdiff) in mg/dL.

Abbreviations: DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, Tg = triglycerides.

This figure presents meta-regression results of effect of EPA+DHA on net change in triglycerides, using EPA+DHA dose as a predictor for the model. This graph displays a negative association of mean EPA+DHA dose on net change triglycerides in mg/dL.

#### Marine Oil, Comparison of Different Doses

Six RCTs directly compared different doses of marine oils (EPA+DHA),75, 97, 169, 177, 194, 195 between 0.7 and 4 g/d. The trials compared EPA+DHA doses between 0.7 and 4 g/d. Only one of the six trials found a significant difference between higher (3.4 g/d) and lower (1.7 g/d) EPA+DHA (ethyl esters).169 Although, most trials found no significant difference, the differences in effect on Tg between doses ranged from −39 to 6 mg/dL. A possible pattern could be discerned such that higher doses of 3.4 or 4 g/d reduced Tg by at least 30 mg/dL more than lower doses of 1 to 2 g/d (Brinton 2013: 4 vs. 2 g/d; Oh 2014: 4 vs 2 g/d and 2 vs. 1 g/d; Tatsuno 2013: 3.4 vs. 1.7 g/d). Higher doses ≤3 g/d (1.7–3 g/d) yielded much smaller relative differences in Tg change compared to lower doses (0.7–2.25 g/d) (−17 to 6 mg/dL) (Caslake 2008: 1.8 vs. 0.7 g/d; Finnegan 2003: 1.7 vs. 0.8 g/d; Kastelein 2014: 3 vs. 2.25 g/d, 3 vs. 1.5 g/d, and 2.25 vs. 1.5 g/d; Oh 2014: 2 vs. 1 g/d).

#### ALA Versus Placebo

Five trials compared ALA supplementation versus placebo (or equivalent), following 4940 patients for 1 to 40 months; one in healthy people,75 three in people at increased risk for CVD,152, 167, 180 and one in people with CVD.119 Doses of ALA ranged from 1.4 to 5.9 g/d, and baseline Tg measurements ranged from 144 to 150 mg/dL. Compliance was measured in all studies, but not reported. All trials found no significant effect of total n-3 FA supplementation on Tg; the estimates of the net differences ranged from −22 to 22, mostly with wide confidence intervals.

#### SDA Versus Placebo

Pieters 2015 compared 1.2 g/d SDA to placebo in 32 patients at risk for CVD. At 1.5 month followup, no significant differences in change in Tg were found.188

#### SDA Versus Marine Oil

Kuhnt 2014 compared 2.0 g/d SDA and 1.9 g/d EPA+DHA+DPA in 59 healthy people (broken into cohorts based on body mass index and age). At 2 month followup, no significant differences in change in Tg were found.178

#### Comparison of Different Specific n-3 FA

Two trials directly compared EPA (3.8 or 3.3 g/d) to DHA (3.6 or 3.7 g/d), one of which evaluated EPA and DHA ethyl esters,61 one of which evaluated EPA- and DHA-enriched oils.107 Neither found a significant difference in effect on Tg between EPA and DHA. One trial compared two doses of EPA+DHA (3.4 and 1.7 g/d) to EPA 1.8 g/d (all ethyl esters),169 finding significantly larger net reductions in Tg with either dose of EPA+DHA than EPA alone. Two trials compared EPA+DHA to ALA, one comparing two doses of EPA+DHA (1.7 and 0.8 g/d) to ALA 4.5 g/d,75 one comparing 0.4 g/d EPA+DHA to 2 g/d ALA.119 A possible dose effect of EPA+DHA was found in that the comparison with the highest dose of EPA+DHA (1.7 g/d) found a significantly greater effect of EPA+DHA than ALA (−28 mg/dL; 95% CI −49 to −7) (Finnegan 2003), while in the same study a lower dose (0.8 g/d) had a smaller nonsignificant difference (−14 mg/dL), and the other study (Kromhout 2010), with EPA+DHA 0.4 g/d had no differential effect (2.7 mg/dL).

### Observational Studies

Observational studies did not evaluate Tg.

## Total Cholesterol to HDL-c Ratio

### Randomized Controlled Trials

Eleven RCTs provided data on effect of n-3 FA on the ratio of total cholesterol to HDL-c (Total:HDL-c) (Table 44),61, 115, 116, 119, 136, 166, 167, 169, 177, 180, 188 one in a healthy population, eight in people at increased risk for CVD, and one in patients with CVD. Two of the trial reported Total:HDL-c among their primary outcomes (Grimsgaard 1998, Rodriguez-Leyva 2013).61, 167

Table 44 Total cholesterol to HDL-c ratio: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int N | Int Baseline | Ctrl N | Ctrl Baseline | Net Chg | Reported P value
Total n-3 FA vs Placebo
Jones 2014 24829493 Canada | At risk | ALA+EPA+DHA | 3.5 g/d (suppl) | Placebo | ALA 0.2 g/d (Canola oil) | 1 mo | Meal consumption | 130 | 4.01 | 130 | 4.24 | −0.1 (−0.3, 0.04) | <0.05
Kromhout 2010 20929341 Netherlands | CVD | ALA+EPA+DHA no statin | 2.4 g/d (Marine, Plant oil) | Placebo, no statin | 0 | 3.4 y | nd | 96 | nd | 113 | nd | 0.14 (−0.11, 0.39)
| | ALA+EPA+DHA + Statin | 2.4 g/d (Marine, Plant oil) | Placebo + Statin | 0 | 3.4 y | nd | 947 | nd | 943 | nd | −0.04 (−0.11, 0.04)
Marine oil vs Placebo
Grimsgaard 1998 9665096 Scandinavia | Healthy | EPA | 3.8 g/d (Ethyl ester) | Placebo | 0 | 2 mo | Pill count | 75 | 4.70 | 77 | 4.43 | −0.2 (−0.4, −0.1) | 0.007
| Healthy | DHA | 3.6 g/d (Ethyl ester) | Placebo | 0 | 2 mo | Pill count | 72 | 4.62 | 77 | 4.43 | −0.3 (−0.5, −0.1) | 0.0006
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 3.34 | 71 | 3.53 | −0.07 (−0.35, 0.21) | nd
| | EPA+DHA | 0.9 g/d (suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 81 | 3.34 | 71 | 3.53 | −0.03 (−0.31, 0.25) | nd
| | EPA+DHA | 0.45 g/d ( suppl=marine oil) | Placebo | 0 | 1 y | Pill Count, Plasma Check | 80 | 3.49 | 71 | 3.53 | −0.01 (−0.29, 0.27) | nd
Einvik 2010 20389249 Scandinavia | At risk | EPA+DHA | 2.4 g/d (Marine oil) [E:D 1.4] | Placebo | 0 | 3 y | Pill count | 70 | 4.8 | 68 | 4.7 | −0.3 (−0.8, 0.2)
| | EPA+DHA + diet intervention | 2.4 g/d (Marine oil) [E:D 1.4] | Placebo + diet intervention | 0 | 3 y | Pill count | 69 | 4.8 | 71 | 4.6 | −0.3 (−0.7, 0.1)
Kastelein 2014 24528690 World | At risk | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | Placebo | 0 | 3 mo | nd | 99 | 9.0 | 98 | 8.8 | −1.2 (−1.9, −0.4) | <0.01
| | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | Placebo | 0 | 3 mo | nd | 97 | 8.9 | 98 | 8.8 | −0.7 (−1.5, 0) | <0.05
| | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | Placebo | 0 | 3 mo | nd | 99 | 8.8 | 98 | 8.8 | −1.0 (−1.8, −0.3) | <0.05
Maki 2010 20451686 U.S. | At risk | EPA+DHA (+simvastatin) | 3.36 g/d (Marine oil) [E:D 1.24] | Placebo (+simvastatin) | 0 | 2 mo | nd | 122 | 4.0 | 132 | 4.3 | −0.3 (−0.5, −0.1) | <0.001
Maki 2013 23998969 U.S. | At risk | EPA+DHA | 4 g/d total oil (free FA oil) [nd] | Placebo | 0 | 1.5 mo | nd | 207 | 4.9 | 211 | 4.7 | −0.2 (−0.3, −0.1) | <0.001
| | EPA+DHA | 2 g/d total oil (free FA oil) [nd] | Placebo | 0 | 1.5 mo | nd | 209 | 4.8 | 211 | 4.7 | −0.1 (−0.2, 0.05) | NS
Jones 2014 24829493 Canada | At risk | EPA+DHA (+ALA) | EPA: 0.1 g/d, DHA: 3.5 g/d, DPA: 1.4 g/d (canola+DHA) | (ALA) | 0 | 1 mo | Meal consumption | 130 | 4.01 | 130 | 4.29 | −0.3 (−0.4, −0.1) | <0.05
Kromhout 2010 20929341 Netherlands | CVD | EPA+DHA | 0.4 g/d (Marine oil) [E:D 1.5] | Placebo | 0 | 3.4 y | nd | 102 | nd | 113 | nd | 0.09 (−0.15, 0.33)
| | EPA+DHA + Statin | 0.4 g/d (Marine oil) [E:D 1.5] | Placebo + Statin | 0 | 3.4 y | nd | 920 | nd | 943 | nd | −0.07 (−0.14, 0.01)
Marine oil vs marine oil (doses)
Sanders 2011 21865334 UK | Healthy | EPA+DHA | 1.8 g/d( suppl=marine oil) | EPA+DHA | 0.9 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 3.34 | 81 | 3.34 | −0.04 (−0.30, 0.22) | nd
| | EPA+DHA | 1.8 g/d (marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 80 | 3.34 | 80 | 3.49 | −0.06 (−0.33, 0.21) | nd
| | EPA+DHA | 0.9 g/d (marine oil) | EPA+DHA | 0.45 g/d (marine oil) | 1 y | Pill Count, Plasma Check | 81 | 3.34 | 80 | 3.49 | −0.02 (−0.28, 0.24) | nd
Kastelein 2014 24528690 World | At risk | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | 3 mo | nd | 99 | 9.0 | 97 | 8.9 | −0.4 (−1.1, 0.3)
| | EPA+DHA | 3 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | 3 mo | nd | 99 | 9.0 | 99 | 8.8 | −0.1 (−0.9, 0.6)
| | EPA+DHA | 2.25 g/d (Marine oil) [E:D 2.75] | EPA+DHA | 1.5 g/d (Marine oil) [E:D 2.75] | 3 mo | nd | 97 | 8.9 | 99 | 8.8 | 0.3 (−0.5, 1.0)
Maki 2013 23998969 U.S. | At risk | EPA+DHA | 4 g/d total oil (free FA oil) [nd] | EPA+DHA | 2 g/d total oil (free FA oil) [nd] | 1.5 mo | nd | 207 | 4.9 | 209 | 4.8 | −0.1 (−0.2, 0.05)
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA +DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 1 y | nd | 170 | nd | 165 | nd | −0.5% (−3.9, 2.9)
Marine oil vs Marine oil (miscellaneous)
Grimsgaard 1998 9665096 Scandinavia | Healthy | EPA | 3.8 g/d (Ethyl ester) | DHA | 3.6 g/d (Ethyl ester) | 2 mo | Pill count | 72 | 4.62 | 75 | 4.70 | 0.1 (−0.1, 0.2) | 0.4
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | −1.4% (−4.9, 2.1)
| | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | −0.9% (−3.9, 2.2)
ALA vs Placebo
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (Canola oil) | Placebo | ALA 0.2 g/d (Canola oil) | 1 mo | Meal consumption | 130 | 4.29 | 130 | 4.24 | 0.2 (0.001, 0.3)
| | ALA | 1.4 g/d (Canola Oleic oil) | Placebo | ALA 0.2 g/d (Canola oil) | 1 mo | Meal consumption | 130 | 4.29 | 130 | 4.24 | 0.1 (−0.001, 0.3)
Rodriguez-Leyva 2013 24126178 Canada | At risk | ALA | 5.9 g/d (flaxseed) | Placebo | 0 | 1 y | Plasma ALA and enterolignan levels | 43 | 3.8 | 41 | 4.0 | 0.2 (−0.3, 0.7) | 0.62
Kromhout 2010 20929341 Netherlands | CVD | ALA | 2 g/d (Plant oil) | Placebo | 0 | 3.4 y | nd | 102 | nd | 113 | nd | 0.07 (−0.17, 0.31)
| | ALA + Statin | 2 g/d (Plant oil) | Placebo + Statin | 0 | 3.4 y | nd | 930 | nd | 943 | nd | 0.06 (−0.02, 0.13)
ALA vs ALA (doses)
Jones 2014 24829493 Canada | At risk | ALA | 5.9 g/d (Canola oil) | ALA | 1.4 g/d (Canola Oleic oil) | 1 mo | Meal consumption | 130 | 4.29 | 130 | 4.29 | 0.02 (−0.1, 0.2) | NS
SDA vs Placebo
Pieters 2015 25226826 Netherlands | At risk | SDA | 1.2 g/d (suppl) | Placebo | 0 | 1.5 mo | nd | 32 | 4.32 | 32 | 4.37 | −0.06 (−0.21, 0.10) | 0.48

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, FA = fatty acid(s), HDL-c = high density lipoprotein cholesterol, Int = intervention, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, ND = no data, NS = not significant, PMID = PubMed Identification number, RCT = randomized controlled trial, SDA = stearidonic acid.

#### Total n-3 FA Versus Placebo

Two trials compared total n-3 FA (ALA+EPA+DHA) versus placebo, following 2708 patients for 1 and 40 months; one in people at increased risk for CVD,180 one in people with CVD.119 Doses of ALA+EPA+DHA included ALA 1.2 g/d and EPA+DHA+DPA 5 g/d, and ALA 2 g/d and EPA+DHA 0.4 g/d. Baseline Total:HDL-c ratio was 4.0 in one trial and not reported in the other. Compliance was measured in both studies, but not reported. The estimates of the net differences were not significant, one with a wide confidence interval.

#### Marine Oil Versus Placebo

Eight trials compared marine oil supplementation to placebo.61, 115, 116, 119, 136, 166, 177, 180 Six of eight trials found statistically significant reductions in Total:HDL-c ratios. Across populations, by meta-analysis, the summary net difference in Total:HDL-c ratio with EPA+DHA versus placebo was a statistically significant −0.17 (95% CI −0.26 to −0.09) (Figure 42). Across studies, by metaregression, effect sizes did not statistically differ by population (at risk P=0.57, CVD P=0.61), marine oil dose (P=0.67), or baseline ratio (P=0.16).

Figure 42 Total cholesterol to HDL-c ratio: Randomized trials of marine oils

Random effects model meta-analysis of n-3 FA versus placebo (or no n-3 FA), with subgroup analyses by population. In all meta-analyses, only studies that reported sufficient results data are included.

Abbreviations: CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, n-3 FA = omega-3 fatty acid, Phet = P value of chi-squared test of heterogeneity across studies, PMID = PubMed Identification number.

This figure presents meta-analysis results for total cholesterol to high density lipoprotein cholesterol ratio in randomized controls that looked at comparisons between marine oil omega-3 fatty acid intake versus a placebo. The meta-analysis was divided into healthy (two studies) at risk (six cohorts) and cardiovascular disease (two cohorts) populations. Subgroup meta-analysis of the healthy, at risk and cardiovascular disease populations yielded significant and nonsignificant summaries of −0.16 (−0.32, 0.01), −0.24 (−0.35, −0.14), and −0.03 (−0.17, 0.10), respectively. The overall summary −0.17 (−0.26, −0.09), was also significant. Net differences across studies were mostly homogeneous.

##### Healthy Population

Two trials compared both EPA, DHA, and EPA+DHA separately to a placebo in 536 healthy participants, total.61, 136 Compliance was assessed with pill count and plasma checks. The baseline Total:HDL-c ratio in the placebo group ranged from 3.53 to 4.43 and followup ranged from 2 months to 1 year. The Grimsgaard trial found significant reductions with both ethyl ester marine oils compared to placebo (−0.2 and −0.3). While the Sanders trial found nonsignificant net change results between interventions and placebo. The two trials yielded a subgroup meta-analysis summary effect of −0.16 (95% CI −0.32 to −0.01).

##### At-Risk-for-CVD Population

Six trials compared EPA+DHA to placebo in 1185 people at increased risk for CVD.115, 116, 119, 166, 177, 180 Compliance was assessed by pill count or meal consumption in two trials. EPA+DHA dosages ranged from 1.5 to 5 g/d and followup ranged from 1 month to 3 years. Baseline Total:HDL-c ratios ranged from 4.29 to 4.7 in four trials and was 8.8 in one trial of patients (Kastelein 2014) with severe hypertriglyceridemia (≥500 mg/dL) at baseline.177 All but one trial found a significant reduction in Total:HDL-c ratio. Net change Total:HDL-c ratio varied between −1.2 and −0.1. The pooled effect size was a statistically nonsignificant −0.24 (95% CI −0.35 to −0.14). Exclusion of Kastelein 2014 did not substantially affect the pooled estimate.

##### CVD Population

One trial compared 3 months of 0.4 g/d EPA+DHA in patients with CVD and found a net change of −0.03 (95% CI −0.17 to 0.10).119 Separate analyses were reported for patient taking statins or not. The study did not report compliance information. Baseline Total:HDL-c ratio data were also not reported. In both subgroups, no significant change in Total:HDL-c ratio was found, but there was a net increase in the ratio (0.09) in patients not taking statins and a net decrease in the ratio (−0.07) in those on statins.

##### RCT Subgroup Analyses

In the trial of patients with CVD, there was no apparent difference in effect on Total:HDL-c ratio based on cointervention with statins.119 In a trial of people at increased risk of CVD, there was no interaction between EPA+DHA and general diet counseling.

By meta-regression, across studies there were no significant differences in effect (interactions) followup duration (P=0.17). However, the at risk for CVD population, mean baseline Total:HDL-c ratio level and EPA+DHA dose across studies were significantly associated with net change Total:HDL-c ratio. Controlling for these three variables, each increase in mean baseline Total:HDL-c level by 1 was associated with a greater net change Total:HDL-c of −0.16 (95% CI −0.25 to −0.07; P=0.0008). Each increase of EPA+DHA dose by 1 g/d was also associated with a greater net change Total:HDL-c of −0.07 (95% CI −0.11 to −0.02; P=0.003). The at risk for CVD population was associated with a greater net change Total:HDL-c of 0.77 (95% CI 0.29 to 1.25; P=0.002).

#### Marine Oil, Comparison of Different Doses

As noted, the trial of people with severe hypertriglyceridemia compared three doses of EPA+DHA (3, 2.25, and 1.5 g/d).177 At 3 month followup, the net differences among the three doses were not significantly different from each other. A second trial, comparing 2 and 4 g/d of total oil (of EPA+DHA) also found no significant differences in effect between the two doses at 1.5 months.166 A third trial, comparing 3.36 g/d 1.68 g/d of EPA+DHA also found no significant differences in effect between the two doses at 1 year.

#### ALA Versus Placebo

Three trials evaluated ALA versus placebo.119, 167, 180 In a trial of people at increased risk for CVD, no significant effects of ALA (both 1.4 and 5.9 g/d) were found on Total:HDL-c ratios at 1 month in 390 participants.180 No difference in effect between the two doses was found in this trial. Similarly no significant effects were found in a trial of 2 g/d ALA in 2,088 people with CVD at 3.4 years.119 or in a trial of 5.9 g/d ALA in 48 people at 1 year.167

#### Comparison of Different Specific n-3 FA

Grimsgaard 1998 compared EPA 3.8 g/d and DHA 3.6 g/d ethyl esters in 157 healthy people for 2 months. No difference in net change Total:HDL-c ratio was found.61 Tatsuno 2013 compared two doses of EPA+DHA (3.36 and 1.68 g/d) to EPA 1.8 g/d alone (all ethyl esters).169 Again, no differences in effect on Total:HDL-c ratio were found. Jones 2014 compared 5.9 g/d and 1.4 g/d of ALA. Again, no difference in effect on Total:HDL-c ratio were found.180

#### SDA Versus Placebo

Pieters 2015 compared 1.2 g/d SDA to placebo in 32 patients at risk for CVD. At 1.5 month followup, no significant differences in change Total:HDL-c ratio were found.188

### Observational Studies

Observational studies did not evaluate Total:HDL-c ratio.

## LDL-c to HDL-c Ratio

### Randomized Controlled Trials

Five RCTs provided data on effect of n-3 FA on the ratio of LDL-c to HDL-c (LDL:HDL-c) (Table 45),46, 76, 167, 169, 178 one studied a healthy population, while four looked at people at increased risk for CVD. Two of the trials reported LDL:HDL-c among their primary outcomes (Rodriguez-Leyva 2013, Shidfar 2003).76, 167

Table 45 LDL-c to HDL-c ratio: RCTs

Study Year PMID Region | Population | Int (n3 FA) | Int n3 Dose (Source) [E:D; n6:3] | Control | Ctrl n3 Dose (Source) [E:D; n6:3] | F/up Time | Compliance Verification | Int N | Int Baseline | Ctrl N | Ctrl Baseline | Net Chg | Reported P value
Marine oil vs Placebo
Liu 2003 Sweden | At risk | EPA+DHA | 2.8 g/d (Marine oil) [E:D 1.55] | Placebo | 0 | 3 mo | Pill count | 29 | 3.20 | 22 | 3.11 | −0.02 (−0.45, 0.41) | NS
| | EPA+DHA+ simvastatin | 2.8 g/d (Marine oil) [E:D 1.55] | Placebo + simvastatin | 0 | 3 mo | Pill count | 19 | 3.28 | 18 | 3.02 | −0.1 (−0.7, 0.5) | NS
Shidfar 2003 12847992 Iran | At risk | EPA+DHA | EPA 0.5 g/d, DHA 0.31 g/d (suppl) [E:D 1.6] | Placebo | 0 | 2.5 mo | nd | 16 | 4.42 | 19 | 4.2 | −0.3 (−1.5, 0.9)
| | EPA+DHA+ vitamin C | EPA 0.5 g/d, DHA 0.31 g/d (suppl) [E:D 1.6] | Placebo + vitamin C | 0 | 2.5 mo | nd | 16 | 4.4 | 17 | 4.3 | 0.2 (−1.1, 1.5)
Marine oil vs Marine oil (doses)
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | 1 y | nd | 170 | nd | 165 | nd | 2.6% (−1.5, 6.7)
Marine oil vs Marine oil (miscellaneous)
Tatsuno 2013 24314359 Japan | At risk | EPA+DHA | 3.36 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | 1.8% (−2.4, 5.9)
| At risk | EPA+DHA | 1.68 g/d (Ethyl esters) E:D 1.24 | EPA | 1.8 g/d (Ethyl ester) | 1 y | nd | 170 | nd | 165 | nd | −0.9% (−4.5, 2.8)
ALA vs Placebo
Rodriguez-Leyva 2013 24126178 Canada | At risk | ALA | 5.9 g/d (flaxseed) | Placebo | 0 | 1 y | Plasma ALA and enterolignan levels | 43 | 2.2 | 41 | 2.2 | 0.1 (−0.3, 0.5) | 0.57
SDA vs Marine oil
Kuhnt 2014 24553695 Germany | Healthy | SDA | 2.0 g/d (suppl) | EPA+DHA+DPA | 1.9 g/d (suppl: marine oil) | 2 mo | nd | 20 | 1.87 | 10 | 1.58 | 0.02 (−0.45, 0.49)
Kuhnt 2014 24553695 Germany | Healthy | SDA | 2.0 g/d (suppl) | EPA+DHA+DPA | 1.9 g/d (suppl: marine oil) | 2 mo | nd | 20 | 2.36 | 9 | 1.81 | 0.03 (−0.59, 0.65)

Abbreviations: ALA = alphalinolenic acid, Ctrl = control, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, E:D = EPA to DHA ratio, EPA = eicosapentaenoic acid, F/up = followup, HDL-c = high density lipoprotein cholesterol, Int = intervention, LDL-c = low density lipoprotein cholesterol, n/N = number with outcome/number analyzed, n6:3 = omega-6 to omega-3 fatty acid ratio, n-3 FA = omega-3 fatty acids, ND = no data, NS = not significant, PMID = PubMed Identification number, RCT = randomized controlled trial, SDA = stearidonic acid.

#### Marine Oil Versus Placebo

Liu 2003 compared 2.8 g/d of EPA+DHA to placebo in 88 people at increased risk for CVD.46 Baseline LDL:HDL-c ratio was about 3.1. Analyses were reported separately for a factorial analysis with simvastatin. At 3 month followup, no effect of LDL:HDL-c ratio was found with EPA+DHA supplementation in either subgroup, with no difference in effect regardless of simvastatin cotreatment.

Shidfar 2003 compared 0.81 g/d of EPA+DHA to placebo in 68 people at increased risk for CVD.76 Baseline LDL:HDL-c ratio was about 4.2. Analyses were reported separately for a factorial analysis with vitamin C. At 2.5 month followup, no effect of LDL:HDL-c ratio was found with total n-3 FA supplementation in either subgroup, with no difference in effect regardless of vitamin C cosupplementation.

Tatsuno 2013 (in a trial without a placebo arm) compared 3.36 and 1.68 g/d EPA+DHA ethyl esters in 335 people at increased risk for CVD.169 At 3 month followup, no significant difference in change in LDL:HDL-c ratio was found.

#### ALA Versus Placebo

One trial evaluated ALA versus placebo.167 In 84 people at increased risk for CVD, no significant effects of ALA (5.9 g/d) were found on LDL:HDL-c ratios at 1 year.

#### Comparison of Different Specific n-3 FA

Tatsuno 2013 compared 3.36 and 1.68 g/d EPA+DHA and 1.8 g/d EPA (all ethyl esters) in 502 people at increased risk for CVD.169 At 3 month followup, no significant differences in change in LDL:HDL-c ratios were found.

#### SDA Versus Marine Oil

Kuhnt 2014 compared 2.0 g/d SDA and 1.9 g/d EPA+DHA+DPA in 59 healthy people (broken into cohorts based on body mass index and age). At 2 month followup, no significant differences in change in LDL:HDL-c ratios were found.178

### Observational Studies

Observational studies did not evaluate Total:HDL-c ratio.

## Adverse Events

Of 61 RCTs included in this systematic review, only 4 RCTs of EPA/DHA ethyl ester, 19 RCTs of marine oils (EPA+DHA), 1 RCT of ALA, and 1 RCT comparing total n-3 FA, marine oil, ALA, and placebo reported information on adverse events that may or may not be associated with the interventions (Table 46).53, 58, 61, 62, 70, 81, 87, 90, 96, 99, 115, 116, 119, 123, 133, 147, 151, 157, 166, 167, 169, 174, 177, 184, 187 There were no serious adverse events that were considered related to the study interventions in these 25 RCTs. Four of the 20 marine oil RCTs and one of the two ALA trials reported no adverse events. Most of the reported adverse events were mild and transient, such as gastrointestinal discomforts, nausea, skin abnormalities, eczema, pain, allergic reactions, fishy taste, headache, and infection. The most common adverse events related to n-3 FA supplements (that occurred more frequently among those taking supplements) were mild gastrointestinal effects such as belching (0.4–58% [marine oil] vs. 1.7–4% [placebo]; 2 studies), nausea (3.6–8.9% vs. 1.0–5.6%, 2 studies), diarrhea (5.1–8.9% vs. 2.0%, 1 study), or fishy taste (5.3–67% vs. 0–3%, 2 studies), or combined gastrointestinal symptoms (e.g., nausea, diarrhea, or epigastric discomfort) (marine oil: 1.5.0–6% vs. 0.8–4.5%, 7 studies; total n-3 FA: 1.3% vs. 0.8%, 1 study; ALA: 0.8% vs. 0.8%). Only one study explicitly reported on bleeding (hemorrhages such as cerebral and fundal bleedings, epistaxis, and subcutaneous bleeding), finding a higher rate with EPA ethyl ester and statin (1.1%) versus statin alone (0.6%, P<0.0001) (Yokoyama 2007). This study was one of only two trials that reported statistically significantly more adverse events with marine oils than placebo (Yokoyama 2007, Kastelein 2014 [total adverse events only]; see Table 42). No study reported statistically significant higher rates of serious or severe adverse events between study arms, and no serious or severe adverse event was attributed to n-3 FA. Six of the marine oil trials explicit stated that most or all adverse events were mild (Einvik 2010, Grimsgaard 1998, Ras 2014, Shaikh 2014, Tatsuno 2013, Yokoyama 2007). Three studies reported on the rate of adverse events leading to discontinuation, none of which were reported as statistically significantly different between groups (1.4–17% vs. 0.9–26%).

Table 46 Adverse events

Study Year PMID Region (Population) | F/up Time | n-3 FA (N) | Dose | AE n-3 FA | Control (N) | AE Control | P-Value | Note
EPA or DHA ethyl ester
Ballantyne 2012 22819432 U.S. (High CVD risk) | 3 mo | EPA+DHA (233) | 4 g/d | Total: 45.5% Eructations: 0.9% Serious AEs^§^: 3.0% | Placebo (233) | Total: 48.1% Eructations: 1.7% Serious AEs: 2.1% | | “No serious AEs were considered related to study drug.”
(High CVD risk) | | EPA+DHA (236) | 2 g/d | Total: 44.9% Eructations: 0.4% Serious AEs: 2.5%
Grimsgaard 1998 9280188 Norway (Healthy) | 2 mo | EPA (75) | 3.8 g/d | Belching: 57% Fishy taste: 65% | Placebo (77) | Belching: 4% Fishy taste: 3% | | “Adverse effects were mild and transient”
| | DHA (72) | 3.6 g/d | Belching: 58% Fishy taste: 67%
Tatsuno 2013 24314359 Japan (Dyslipidemia) | 1 y | EPA+DHA (167) | 3.36 g/d | Total: 9.9% Gastritis: 3.5% Constipation: 3.5% Eczema: 4.1% | | | | “Most AEs were mild or moderate in severity.”
| | EPA+DHA (171) | 1.68 g/d | Total: 13.3% Gastritis: 3.6% Constipation: 1.8% Eczema: 3.0%
| | EPA (165) | 1.8 g/d | Total: 12.6% Gastritis: 2.4% Constipation: 0.0% Eczema: 1.2%
Yokoyama 2007 17398308 Japan (Dyslipidemia) | 5 y | EPA + statin (9326) | 1.8 g/d | Total: 25.3% Abnl lab data: 4.1% GI^*^: 3.8% Skin^†^: 1.7% Hemorrhage^‡^: 1.1% | Statin (9319) | Total 21.7% Abnl lab data: 3.5% GI: 1.7% Skin: 0.7% Hemorrhage: 0.6% | Total <0.0001 Abnl lab data: 0.04 GI: <0.0001 Skin: <0.0001 Hemorrhage: <0.0001 | “Most adverse effects attributable to EPA allocation were regarded as mild.”
Marine oils (EPA+DHA)
Brouwer 2006 16772624 N. Europe (CVD) | 1 y | EPA+DHA (273) | 0.96 g/d | GI^*^: 6% | Placebo (273) | GI^*^: 4% | NS (implied)
Carter 2012 22707560 U.S. (Healthy) | 2 mo | EPA+DHA (19) | 2.7 g/d | 0% | Placebo (19) | 0% | | No AEs reported
Einvik 2010 20389249 Norway (Dyslipidemia) | 3 y | EPA+DHA (282) | 2.4 g/d | Regurgitation: 4% | Placebo (281) | Regurgitation: 0% | | “Side effects were mild and without consequence”
Galan 2010 21115589 France (CVD) | 4.7 y | EPA+DHA (633) | 0.6 g/d | Side effects^††^: 2.6% | Placebo (626) | Side effects: 1.6%
Holman 2009 19002433 UK (Diabetes) | 4 mo | EPA+DHA (197) | 2 g/d | Serious AEs^§^: 10% | Placebo (202) | Serious AEs: 9% | 0.082 | “There were no significant differences in nonserious AE between groups.”
| | EPA + DHA +atorvastatin (200) | 2 g/d | Serious AEs: 17% | Placebo + atorvastatin (201) | Serious AEs: 7%
Kastelein 2014 24528690 Europe (Dyslipidemia) | 12 wk | EPA+DHA (99) | 3.0 g/d | Total: 44.4% AEs related to treatment: 25.3% Severe AEs^‡‡^: 1.0% Diarrhea: 10.1% Nausea: 5.1% Vomiting: 0% Abdominal pain: 1.0% | Placebo (99) | Total: 26.3% AEs related to treatment: 3.0% Severe AEs^§§^: 5.1% Diarrhea: 2.0% Nausea: 1.0% Vomiting: 1.0% Abdominal pain: 1.0% | Total: 0.036
| | EPA+DHA (101) | EPA: 2.25 g/d | Total: 42.6% AEs related to treatment: 16.8% Severe AEs\|\|\|\|: 3.0% Diarrhea: 5.9% Nausea: 8.9% Vomiting: 4.0% Abdominal pain: 1.0%
| | EPA+DHA (100) | EPA: 1.50 g/d | Total: 40.0% AEs related to treatment: 18.0% Severe AEs^¶¶^: 2.0% Diarrhea: 10.0% Nausea: 6.0% Vomiting: 2.0% Abdominal pain: 4.0%
Lungershausen 1994 7852747 Australia (Hypertension) | 1.5 mo | EPA+DHA (42) | 3.4 g/d | 0% | Placebo (42) | 0% | | No AEs reported
Macchia 2013 23265344 Argentina and Italy (CVD) | 12 mo | EPA+DHA (289) | 0.85–0.882 | GI^*^: 2.0% | Placebo (297) | GI^*^: 2.7%
Maki 2010 20451686 U.S. (Dyslipidemia) | 8 wk | EPA+DHA + simvastatin (122) | 3.36 g/d | | Placebo + simvastatin (132) | | | “There was no significant difference in the frequency of AEs between groups. No serious AEs were considered treatment related.”
Maki 2013 23998969 U.S. (Dyslipidemia) | 1.5 mo | EPA+DHA (216) | 4 g/d | Total: 41.7% Serious AEs\|\|: 0.5% AEs related to treatment: 20.4% AEs leading to discontinuation: 3.2% | Placebo (216) | Total: 27.9% Serious AEs^¶^: 1.4% AEs related to treatment: 6.0% AEs leading to discontinuation: 0.9%
| | EPA+DHA (215) | 2 g/d | Total: 33.0% Serious AEs^**^: 1.4% AEs related to treatment: 9.8% AEs leading to discontinuation: 1.4%
Marchioli 2002 11997274 Italy (CVD) | 3.5 y | EPA+DHA (5666) | 0.850–0.882 g/d | 0% | No intervention (5668) | 0% | | No AEs reported.
Nodari 2011 21844082 Italy (CVD) | 1 y | EPA+DHA (94) | 0.850–0.882 g/d | Total: 2.1% | Placebo (94) | Total: 3.2%
Raitt 2005 15956633 U.S. (CVD) | 2 y | EPA+DHA (100) | 1.3 g/d | AEs leading to discontinuation: 17% | Placebo (100) | AEs leading to discontinuation: 26% | NS | “No significant differences in serious AEs… possible exception of an excess of hospitalizations for neurologic events inpatients assigned to placebo.”
Ras 2014 25122648 Scandinavia (Healthy) | 1 mo | EPA+DHA (62) | 1.8 g/d | | Placebo (64) | | NS (implied) | “Overall, AEs were mild... There was no remarkable difference in the number of subjects experiencing AEs or in the nature and frequency of AEs between the 5 treatment groups.”
| | EPA+DHA (62) | 1.3 g/d
| | EPA+DHA (64) | 0.9 g/d
Shaikh 2014 25185754 U.S. (Healthy) | 2 mo | EPA+DHA (56) | 3.6 g/d | Fishy belching: 5.3% Flatulence: 3.6% Nausea: 3.6% | Placebo (54) | Fishy belching: 0% Flatulence: 0% Nausea: 5.6% | | “No serious adverse events related to the study treatment were observed.”
Sirtori 1997 9174486 Italy (Dyslipidemia) | 6 mo | EPA+DHA | 2.57 g/d (470) | GI^*^: 3.8% | Placebo (465) | GI^*^: 4.5%
Tavazzi 2008 18757090 Italy (CVD) | 3.9 y | EPA+DHA (3494) | 0.850–0.882 g/d] | AEs leading to discontinuation: 3% GI^*^: 2.7% Allergic reaction: 0.09% | Placebo (3481) | AEs leading to discontinuation: 3% GI^*^: 2.6% Allergic reaction: 0.3% | Discontinuation: 0.87
Vazquez 2014 24462043 Spain (Healthy) | 2 mo | EPA+DHA (273) | 0.64 g/d | 0% | Placebo (273) | 0% | | No AEs reported
von Schacky 1999 10189324 Canada (CVD) | 2 y | EPA+DHA (112) | EPA+DHA 3.3 g/d (3 mo), 1.65 g/d (21 mo) | GI^*^: 3.6% | Placebo (111) | GI^*^: 2.7%
ALA
Rodriguez-Leyva 2013 24126178 Canada (CVD) | 1 y | ALA (59) | 5.9 g/d | 0% | Placebo (52) | 0% | | No AEs reported
Multiple n-3 FA
Kromhout 2010 20929341 Netherlands (CVD) | 40 mo | ALA+EPA+DHA (1212) | 2.4 g/d | GI^*^: 1.3% | Placebo (1236) | GI^*^: 0.8% | NS (implied)
| | EPA+DHA (1192) | 0.4 g/d | GI^*^: 1.5%
| | ALA (1197) | 2.0 g/d | GI^*^: 0.8%

* Such as nausea, diarrhea, or epigastric discomfort.

† Such as eruption, itching, exanthema, or eczema

‡ Such as cerebral and fundal bleedings, epistaxis, and subcutaneous bleeding

§ Not defined.

|| Coronary artery disease (this “adverse event” was included here only because it was grouped within “serious adverse events” and was compared with other events; otherwise it would only be evaluated as a cardiovascular outcome)

¶ Such as intestinal obstruction, bronchitis, and hyperglycemia

** Such as diverticular perforation, musculoskeletal chest pain, and osteoarthritis

†† Gastrointestinal disturbances, nausea, and cutaneous reactions

‡‡ Diarrhea

§§ Myocarditis, abdominal pain, acute sinusitis, ear infection, increased blood triglycerides

|||| Coronary artery disease, pulmonary embolism, implantable defibrillator insertion (these “adverse events” were included here only because they was grouped within “severe adverse events” and were compared with other events; otherwise it would only have been evaluated as cardiovascular outcomes)

¶¶ Microalbuminuria, urticaria.

Abbreviations: Abnl = abnormal, AE = adverse event, ALA = alphalinolenic acid, CVD = cardiovascular disease, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, F/up = followup, GI = gastrointestinal, n-3 FA = omega-3 fatty acids, NS = not significant, PMID = PubMed Identification number.

## Summary by n-3 FA

The trials of clinical outcomes were almost all conducted in populations at increased risk of CVD, largely related to dyslipidemia, or with CVD. The trials that reported intermediate outcomes (BP and lipoproteins), were conducted in generally healthy, at-risk, and CVD populations. The observational studies, in contrast, were almost all conducted in general (unrestricted by CVD or risk factors) or healthy populations. One observational study evaluated BP; none evaluated lipids.

### Total n-3 FA (ALA+EPA+DHA)

Overall, there is insufficient evidence regarding the effect of or association between total n-3 FA (combined ALA and marine oils) and clinical or intermediate outcomes (Table 47). There is low strength of evidence of no association between total n-3 FA intake and stroke death, and total (fatal and nonfatal) MI (each association based on longitudinal observational studies of dietary intake). For both outcomes, the strength of evidence was rated low because of a lack of confirmatory RCT data.

Table 47 Evidence profile for the effect and association of total n-3 FA with CVD outcomes^*^

Outcome | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
Major adverse cardiovascular events (MACE) | Insufficient | RCT: 0 Obs intake: 3 Obs biomarkers: 0 | Low | RCT: NA Obs intake: Inconsistent Obs biomarkers: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: NA | No RCT | RCT: NA Obs intake: Unclear Obs biomarkers: NA
CVD death (including stroke) | Insufficient | RCT: 0 Obs intake: 4 Obs biomarkers: 1 | Low | RCT: NA Obs intake: Inconsistent Obs biomarkers: NA All: Inconsistent | RCT: NA Obs intake: Precise Obs biomarker: Precise | No RCT | RCT: NA Obs intake: Unclear Obs biomarkers: Lower risk
Cardiac death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Coronary heart disease death | Insufficient | RCT: 0 Obs intake: 2 Obs biomarkers: 1 | Moderate | RCT: NA Obs intake: Consistent Obs biomarkers: NA All: inconsistent | RCT: NA Obs intake: Imprecise Obs biomarker: Precise | Sparse | RCT: NA Obs intake: No association Obs biomarkers: Lower risk
Myocardial infarction death | Insufficient | RCT: 0 Obs intake: 2 Obs biomarkers: 0 | Moderate | RCT: Obs intake: Inconsistent Obs biomarkers All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | Sparse | RCT: NA Obs intake: Unclear Obs biomarkers: NA
Heart failure death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Unclear | Sparse | RCT: NA Obs intake: Lower risk Obs biomarkers: NA
Stroke death | Low | RCT: 0 Obs intake: 4 Obs biomarkers: 1 | Low | RCT: NA Obs intake: Consistent Obs biomarkers: NA All: Consistent | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | No RCT | RCT: NA Obs intake: No association Obs biomarkers: No association
Ischemic stroke death | Insufficient | RCT: 0 Obs intake: 2 Obs biomarkers: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Unclear Obs biomarker: NA | Sparse | RCT: NA Obs intake: Lower risk Obs biomarkers: NA
Hemorrhagic stroke death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Death, all-cause | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 1 | Moderate | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Precise Obs biomarker: Precise | Sparse | RCT: NA Obs intake: No association Obs biomarkers: Lower risk
Coronary heart disease | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 2 | Low | RCT: NA Obs: NA Obs biomarkers: Inconsistent All: Consistent | RCT: NA Obs intake: NA Obs biomarker: Precise | Sparse | RCT: NA Obs intake: NA Obs biomarkers: Unclear
Myocardial infarction | Low | RCT: 0 Obs intake: 3 Obs biomarkers: 0 | Low | RCT: NA Obs intake: Consistent Obs biomarkers: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: NA | No RCT | RCT: NA Obs intake: No association Obs biomarkers: NA
Acute coronary syndrome | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Unclear Obs biomarkers: NA | Sparse | RCT: NA Obs intake: No association Obs biomarkers: NA
Angina pectoris | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Atrial fibrillation | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: Unclear | Sparse | RCT: NA Obs intake: NA Obs biomarkers: Lower risk
Congestive heart failure | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 1 | Low | RCT: NA Obs: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: Unclear | Sparse | RCT: NA Obs intake: NA Obs biomarkers: No association
Stroke, total | Insufficient | RCT: 0 Obs: 1 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: NA Obs intake: Imprecise Obs biomarkers: Imprecise | Sparse | RCT: NA Obs intake: No association Obs biomarkers: No association
Stroke, ischemic | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: Imprecise | Sparse | RCT: NA Obs intake: NA Obs biomarkers: Lower risk
Stroke, hemorrhagic | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: NA Obs biomarkers: Imprecise | Sparse | RCT: NA Obs intake: NA Obs biomarkers: No association
Sudden cardiac death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: NA Obs intake: Imprecise Obs biomarkers: Imprecise | Sparse | RCT: NA Obs intake: No association Obs biomarkers: No association
Revascularization | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Hypertension | Insufficient | RCT: 0 Obs intake: 2 Obs biomarkers: 0 | Low | RCT: NA Obs intake: Inconsistent Obs biomarkers: NA All: NA | RCT: NA Obs intake: Precise Obs biomarker: NA | Sparse | RCT: NA Obs intake: Unclear Obs biomarkers: NA
Blood pressure (SBP, DBP, MAP combined) | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarkers: NA
LDL-c | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | No Obs | RCT: No effect Obs intake: NA Obs biomarkers: NA
HDL-c | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | No Obs | RCT: No effect Obs intake: NA Obs biomarkers: NA
Triglycerides | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | No Obs | RCT: Unclear Obs intake: NA Obs biomarkers: NA
HDL-c/Total cholesterol to LDL-c ratios | Insufficient | RCT: 2 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | No Obs | RCT: No effect Obs intake: NA Obs biomarkers: NA

* No reporting bias was detected for any outcome. All studies that measured n-3 FA intake were assessed to be direct, while all biomarker studies were assessed to be indirect.

Abbreviations: CVD = cardiovascular disease, DBP = diastolic blood pressure, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MACE = major adverse cardiovascular event (including cardiac and stroke events and death; variously defined by studies), MAP = mean arterial blood pressure, n-3 FA = omega-3 fatty acids, NA = not applicable, Obs = observational study, RCT = randomized controlled trial, SBP = systolic blood pressure, SoE = strength of evidence.

#### Clinical Event Outcomes, RCTs

No RCTs reported clinical event outcomes for comparisons of total n-3 FA versus placebo.

#### Intermediate Outcomes, RCTs

Two RCTs that evaluated BP compared combined ALA and marine oil (ALA 1.2 g/d [canola oil] or 2 g [“plant oil”], and 3.6 or 0.4 g EPA+DHA) versus placebo reported on intermediate outcomes. Neither trial found significant effects on BP, LDL-c, HDL-c, Tg, or Total:HDL-c ratio.

#### Observational Studies, Intake

Seven studies evaluated total n-3 FA intake. For each outcome there was no consistent (and replicated) significant association between total n-3 FA intake and risk reduction. One of three studies found a significant association between higher total n-3 FA intake and higher risk of MACE. In contrast, one of three studies found an association with reduced risk of CVD death; one of two studies found a significant association with MI death; one study each found significant associations with lower risk of ischemic stroke death and CHF death. No studies found significant associations with all-cause death (1 study), CHD death (2 studies), total (ischemic and hemorrhagic) stroke death (3 studies), MI (1 study), total (fatal and nonfatal) stroke (1 study), SCD (1 study), or incident hypertension (1 study).

One study found no significant difference in association of total n-3 FA with total CVD death between men and women or by amount of fish consumption. Another study found no significant difference in association with MI death, total stroke death, or ischemic stroke death by baseline Total:HDL-c ratio.

#### Observational Studies, Biomarkers

Three studies evaluated biomarkers for total n-3 FA (combined; plasma, blood, or erythrocyte). One study evaluated numerous outcomes and found significant associations between higher biomarker level and reduced risk of most outcomes (CVD death, CHD death, all-cause death, CHD, ischemic stroke, SCD, AFib, and CHF), but not stroke death, total stroke, or hemorrhagic stroke. In contrast, a second study found no significant association with CHD. The third study found no significant association overall with incident hypertension, but did find a significant association in between higher total n-3 FA and hypertension in younger women (<55 years old) but not in older women.

### Marine Oil, Total: EPA+DHA±DPA

Overall, there is low, moderate, or high strength of evidence of no effect (or association) of marine oils and most clinical CVD outcomes and BP, and high strength of evidence of significant effects of higher marine oil intake on lipoproteins and Tg. (Table 48). There is insufficient evidence for many outcomes of interest. Specifically, there is high strength of evidence of that marine oils statistically significantly lower Tg—possibly with greater effects with higher doses and in people with higher baseline Tg—and statistically significantly raise HDL-c and LDL-c by similar amounts. There is also high strength of evidence that marine oil significantly lowers Total:HDL-c ratio and low strength of evidence that marine oil significantly lowers risk of ischemic stroke (for which no RCTs confirmed the observational study finding). There is a high strength of evidence of no effect of marine oil on risk of MACE, all-cause death, SCD, revascularization, and BP, moderate strength of evidence of no effect of marine oil on risk of AFib, and low strength of evidence of no effect of marine oil on risk of CVD death, CHD death, total CHD, MI, CHF, total stroke, and hemorrhagic stroke. Strength of evidence was rated as low for CHD and hemorrhagic stroke due to a lack of confirmatory RCT data; and for CVD death, CHF, and total stroke because RCTs and observational studies yielded conflicting conclusions (RCTs found no effect, observational studies found statistically significant associations). Strength of evidence was rated low for CHD death primarily because RCTs and observational studies both yielded imprecise estimates suggesting no effect/association. For MI, the strength of evidence was rated low primarily because the summary effect size estimate was relatively strong (HR = 0.88), but the 95% CI only minimally crossed the significance threshold (95% CI 0.77 to 1.02); this scenario yielded low confidence that the conclusion would remain stable with future RCTs and subsequent greater statistical power. This issue was also pertinent for CVD death where summary HR = 0.92 (95% CI 0.82 to 1.02). There is insufficient evidence for other outcomes.

Table 48 Evidence profile for the effect and association of marine oil (EPA+DHA± DPA) with CVD outcomes^*^

Outcome | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
Major adverse cardiovascular events (MACE) | High | RCT: 10 Obs intake: 3 Obs biomarkers: 2 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: Inconsistent All: Inconsistent | RCT: Precise Obs intake: Precise Obs biomarker: Precise | None | RCT: No effect 0.96 (0.91, 1.02) Obs intake: No association Obs biomarkers: Unclear
CVD death (including stroke) | Low | RCT: 7 Obs intake: 6 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: Inconsistent Obs biomarkers: NA All: Inconsistent | RCT: Imprecise Obs intake: Imprecise Obs biomarker: NA | None | RCT: No effect 0.92 (0.82, 1.02) Obs intake: Lower risk 0.88 (0.82, 0.95) per g/d Obs biomarkers: NA
Cardiac death | Insufficient | RCT: 5 Obs intake: 1 Obs biomarkers: 1 | Low | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: Inconsistent | RCT: Precise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse Obs | RCT: Unclear Obs intake: No association Obs biomarkers: No association
Coronary heart disease death | Low | RCT: 4 Obs intake: 7 Obs biomarkers: 0 | Moderate | RCT: Consistent Obs intake: Inconsistent Obs biomarker: NA All: Inconsistent | RCT: Imprecise Obs intake: Imprecise Obs biomarker: NA | None | RCT: No effect Obs intake: No association 1.09 (0.76, 1.57) per g/d Obs biomarkers: NA
Myocardial infarction death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: NA Obs: NA Obs intake: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: NA | Sparse | RCT: NA Obs intake: Lower risk Obs biomarkers: NA
Heart failure death | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarkers: NA
Stroke death | Insufficient | RCT: 2 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: Imprecise Obs intake: Imprecise Obs biomarker: NA | Sparse | RCT: No effect Obs intake: No association Obs biomarkers: NA
Ischemic stroke death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Unclear Obs biomarker: NA | Sparse | RCT: NA Obs intake: Lower risk Obs biomarkers: NA
Hemorrhagic stroke death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Unclear Obs biomarker: NA | Sparse | RCT: NA Obs intake: No association Obs biomarkers: NA
Death, all-cause | High | RCT: 17 Obs intake: 3 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: NA All: Inconsistent | RCT: Precise Obs intake: Precise Obs biomarker: NA | None | RCT: No effect 0.97 (0.92, 1.03) Obs intake: No association 0.62 (0.31, 1.25) per g/d Obs biomarkers: NA
Coronary heart disease | Low | RCT: 0 Obs intake: 7 Obs biomarkers: 1 | Low | RCT: NA Obs intake: Consistent Obs biomarkers: NA All: Consistent | RCT: NA Obs intake: Precise Obs biomarker: Precise | No RCT | RCT: NA Obs intake: No association 0.94 (0.81, 1.10) per g/d Obs biomarkers: Lower risk
Myocardial infarction | Low | RCT: 11 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: Imprecise Obs intake: Precise Obs biomarker: NA | Sparse Obs | RCT: No effect 0.88 (0.77, 1.02) Obs intake: No association Obs biomarkers: NA
Acute coronary syndrome | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | Sparse | RCT: NA Obs intake: No association Obs biomarkers: No association
Angina pectoris | Low | RCT: 6 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Inconsistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Heterogeneous outcomes | RCT: No effect Obs intake: NA Obs biomarkers: NA
Atrial fibrillation | Moderate | RCT: 3 Obs intake: 3 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: Inconsistent Obs biomarkers: NA All: Consistent | RCT: Precise Obs intake: Imprecise Obs biomarker: NA | Few studies | RCT: No effect Obs intake: Unclear Obs biomarkers: NA
Ventricular Arrhythmia | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA | RCT: Precise Obs intake: NA Obs biomarkers: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarkers: NA
Congestive heart failure | Low | RCT: 6 Obs intake: 5 Obs biomarkers: 2 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: Consistent All: Inconsistent | RCT: Imprecise Obs intake: Precise Obs biomarker: Imprecise | Few RCTs | RCT: No effect Obs intake: Lower risk 0.76 (0.58, 1.00) per g/d Obs biomarkers: No association
Stroke, total | Low | RCT: 7 Obs intake: 4 Obs biomarkers: 2 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: Inconsistent All: Consistent | RCT: Precise Obs intake: Imprecise Obs biomarker: Imprecise | None | RCT: No effect 0.97 (0.83, 1.13) Obs intake: Lower risk 0.68 (0.53, 0.87) per g/d Obs biomarkers: Unclear
Stroke, ischemic | Low | RCT: 2 Obs intake: 5 Obs biomarkers: 2 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: Inconsistent All: Inconsistent | RCT: Precise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse RCT | RCT: No effect Obs intake: Lower risk 0.51 (0.29, 0.89) per g/d Obs biomarkers: Unclear
Stroke, hemorrhagic | Low | RCT: 2 Obs intake: 5 Obs biomarkers: 1 | Low | RCT: Consistent Obs intake: Consistent Obs biomarkers: NA All: Consistent | RCT: Precise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse RCT | RCT: NA Obs intake: No association 0.61 (0.34, 1.11) per g/d Obs biomarkers: No association
Sudden cardiac death | High | RCT: 9 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: Consistent | RCT: Precise Obs intake: Imprecise Obs biomarkers: NA | None | RCT: No effect 1.04 (0.92, 1.17) Obs intake: No association Obs biomarkers: NA
Revascularization | High | RCT: 6 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: Obs biomarker: | Sparse Obs | RCT: No effect Obs intake: No association Obs biomarkers: NA
Hypertension | Insufficient | RCT: 0 Obs intake: 1 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: NA Obs intake: Precise Obs biomarker: NA | Sparse | RCT: NA Obs intake: No association Obs biomarkers: NA
Blood pressure (SBP, DBP, MAP combined) | High | RCT: 29 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | No Obs | RCT: No effect SBP: 0.1 mmHg (−0.2, 0.4) DBP: −0.2 mmHg (−0.4, 0.05) Obs intake: NA Obs biomarkers: NA
LDL-c | High | RCT: 39 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | No Obs | RCT: Higher risk (raise LDL-c) 1.98 mg/dL (0.38, 3.58) Obs intake: NA Obs biomarkers: NA
HDL-c | High | RCT: 34 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | No Obs | RCT: Lower risk (raise HDL-c) 0.88 mg/dL (0.20, 1.57) Obs intake: NA Obs biomarkers: NA
Triglycerides | High | RCT: 41 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | No Obs | RCT: Lower risk (lower triglycerides) −24 mg/dL (−31, −18) Obs intake: NA Obs biomarkers: NA
HDL-c/Total cholesterol to LDL-c ratios | High | RCT: 11 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | No Obs | RCT: Lower risk −0.17 (−0.26, −0.09) Obs intake: NA Obs biomarkers: NA

* No reporting bias was detected for any outcome. All studies that measured n-3 FA intake were assessed to be direct, while all biomarker studies were assessed to be indirect.

Abbreviations: CVD = cardiovascular disease, DBP = diastolic blood pressure, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MAP = mean arterial blood pressure, n-3 FA = omega-3 fatty acids, NA = not applicable, Obs = observational study, RCT = randomized controlled trial, SBP = systolic blood pressure, SoE = strength of evidence.

Four RCTs explicitly evaluated (purified) EPA and/or DHA ethyl esters;61, 90, 96, 161, 169 all other trials explicitly or implicitly evaluated marine oil preparations. No study directly compared formulations. The effects on clinical and intermediate outcomes found among the ethyl ester trials were all statistically or qualitatively similar to the effects found in other studies.

#### Clinical Event Outcomes, RCTs

Regarding clinical event outcomes, 19 trials in populations at increased risk for CVD (3 RCTs) and CVD populations (17 RCTs) mostly found no significant effects of marine oil (EPA+DHA±DPA) versus placebo on specific clinical event outcomes. Across RCTs, EPA+DHA doses ranged from 0.34 to 6 g/d (median 0.866 g/d). Followup ranged from 1 to over 10 years (median 3.9 years).

Two of 17 trials found significantly lower risk of all-cause death with EPA+DHA (both 0.866 g/d; HR = 0.79 and 0.91), however, the meta-analyzed HR was nonsignificant at 0.97 (95% CI 0.92 to 1.03) with no differences across trials by marine oil dose, followup time, or population (CVD, at risk, healthy). Four trials also found no within-study subgroup differences in effect on death for multiple subgroup comparisons.

Ten RCTs reported on MACE, only two of which found significant reductions in outcome with 0.866 g/d EPA+DHA at 3.9 year followup and with 1.8 g/d EPA at 5 year followup (in an at-risk population, but not in a parallel CVD population). Meta-analysis of MACE found a no effect (HR=0.96; 95% CI 0.91 to 1.02) with no significant differences across studies by marine oil dose (range 0.4–2 g/d), followup time (range 1–5 y), or population category. Within-study subgroup analyses found a significant effect in women but not men in one trial, but no significant difference in effect between sexes in a second trial, and no differences between multiple subgroups in three trials.

None of the 11 trials that reported on total MI found a significant effect. Meta-analysis, however, found a nonsignificant effect size (HR=0.88; 95% CI 0.77 to 1.02), with no significant differences across studies by marine oil dose, followup time, or population category. In one trial, no significant difference in effect was found based on cointervention with B vitamins.

Two of seven RCTs found significant effects of 0.866 g/d marine oil (EPA+DHA) on risk of CVD death in populations of people with existing CVD. Meta-analysis found a nonsignificant effect size (HR=0.92; 95% CI 0.82 to 1.02), with no significant differences across studies by marine oil dose, followup time, or population.

Nine RCTs all found no significant effect of EPA+DHA with SCD; by meta-analysis (with the EPA trial), summary HR=1.04 (95% CI 0.92 to 1.17). Seven RCTs also found no significant effect of marine oils with total stroke; by meta-analysis, summary HR=0.98 (95% CI 0.88 to 1.09).

Six RCTs evaluated angina pectoris, three stable angina, one hospitalization for angina, and three unstable angina. One trial found that 1.8 g/d of purified EPA ethyl ester had an additive effect on statin to reduce unstable angina incidence after 5 years in people with dyslipidemia; however the five trials in people with existing CVD found no significant effects of 0.84 to 6 g/d marine oils. The six RCTs evaluating CHF had a similar pattern. The one trial of 0.85 g/d marine oil in people with multiple risk factors for CHF found a significant risk reduction in CHF hospitalization with n-3 FA supplementation, but the five studies in people with existing CVD found no significant effects of 0.84 to 6 g/d marine oils.

All EPA+DHA RCTs that evaluated revascularization (6 trials), CHD death (4 trials), total stroke death (3 trials), AFib (3 trials), and CHF death (1 trial) found no significant effect of marine oils. One trial found an effect in participants with diabetes that was not seen in those without diabetes, but no test of interaction was reported. Two trials compared effect of marine oils on AFib in multiple subgroups, finding no significant differences.

Four EPA+DHA RCTs found inconsistent effects on cardiac death, with effect sizes ranging from 0.45 to 1.45. One trial found a statistically significant reduction in cardiac death with 0.866 g/d EPA+DHA at 3.5 years (RR=0.65; 95% CI 0.51 to 0.82); one trial found a statistically significant increase in cardiac death with a fish diet with EPA+DHA supplements (0.855 g/d EPA+DHA; HR=1.45; 95% CI 1.05 to 1.99), but no significant effect on cardiac death among people only given advice to increase fish intake (by 0.45 g/d EPA+DHA) or in two other trials of 0.96 and 2.6 g/d EPA+DHA. The trial that found increased risk with combined fish diet and EPA+DHA supplementation found no significant difference in effect between multiple sets of subgroups based on drug cointervention.

#### Intermediate Outcomes, RCTs

Twenty-nine RCTs that compared EPA+DHA to placebo evaluated systolic BP, of which 28 also reported on diastolic BP. Ten RCTs were in healthy populations, 13 in those at risk for CVD, and six in those with CVD. All trials found no significant difference in BP across EPA+DHA doses of 0.30 to 6 g/d and followup durations of 1 month to 6 years. By meta-analysis, no significant effects on systolic (summary net difference = 0.10 mmHg; 95% CI −0.20 to 0.40) or diastolic (summary net difference = −0.19 mmHg; 95% CI −0.43 to 0.05) BP were found. Four of the trials also found no effect on MAP. By meta-regression, no differences in effect across studies were found by marine oil dose, followup duration or population. Three trials directly compared different EPA+DHA doses and found no differences in effect (1.7 vs. 0.8 g/d; 1.8 vs. 0.9 or 0.45 g/d; 3.4 vs. 1.7 g/d). One trial found no difference in effect between people with normal BP or prehypertension.

Numerous included RCTs compared the effect of marine oils and placebo (or equivalent) on blood lipids. Thirty-nine RCTs evaluated LDL-c and 34 evaluated HDL-c. Marine oil doses ranged from 0.3 to 6 g/d (median 2.4 g/d) and study followup times ranged from 1 month to 6 years (median 3 months). Meta-analysis of the effect of marine oils on LDL-c found a statistically significant, but small effect increasing LDL-c (1.98 mg/dL; 95% CI 0.38 to 3.58). Marine oils increased HDL-c also by a statistically significant, but small effect (0.92 mg/dL; 95% CI 0.18 to 1.66). For both lipoprotein fractions, no significant differences in effect across studies were found by marine oil dose, followup duration or population. Seven studies found no significant differences in effect within study by EPA+DHA dose. For HDL-c, three trials found no significant difference in effect between people using statins or not; one or two trials, each, found no significant differences between subgroups based on sex or age. One trial found a larger HDL-c effect in a subgroup also randomized to an exercise regimen; one of two trials found a larger HDL-c effect in people with impaired glucose tolerance compared to those with normoglycemia. Eight trials mostly found no significant effects of marine oil (0.4–5 g/d for 1 month to 3 years) on Total:HDL-c ratio, but with a statistically significant summary effect of −0.17 (95% CI −0.26 to −0.09). One trial of 2.8 g/d EPA+DHA found no significant effect on LDL:HDL-c ratio; another trial found no significant difference in change in ratio between 3.4 and 1.7 g/d EPA+DHA.

Forty-one included RCTs mostly found significant effects of marine oils (0.3–6 g/d; median 2.4 g/d for 1 month to 6 years; median 3 months) on Tg levels. Meta-analysis found a summary net change of −24 mg/dL (95% CI −31 to−18), with no significant difference in effect based on population or followup time across studies. By metaregression, each increase in mean baseline Tg concentration by 1 mg/dL was associated with a greater net decrease in Tg concentration of −0.15 mg/dL (95% CI −0.22 to−0.08; P<0.0001); each increase of EPA+DHA dose by 1 g/d was also associated with a greater net decrease in Tg concentration of −5.9 mg/dL (95% CI −9.9 to−2.0; P=0.003). No clear inflection point was found at any dose. Five of six trials found no significant difference in Tg change by EPA+DHA dose, but across trials all doses of 3.4 and 4 g/d lowered Tg concentration by at least 30 mg/dL more than lower doses (1–2 g/d), while all pairwise comparisons of lower doses (1.7–3 g/d) to even lower doses (0.7–2.25 g/d) found much smaller differences between doses (−17 to 6 mg/dL). Two trials both found significantly larger Tg concentration lowering effects of EPA (3.6 or 3.3 g/d) than DHA (3.8 or 3.7 g/d). No significant differences were found based on statin use (4 trials), vitamin C use (1 trial), concurrent high or low linoleic acid diet (1 trial), concurrent general dietary advice (1 trial), or age (1 trial). One trial found a significantly larger effect on Tg among people also taking a multivitamin. One trial found a larger effect of higher dose EPA+DHA (1.8 g/d) in men than women, but no significant difference between sexes at 0.8 g/d. One trial found no significant difference in effect between people with impaired glucose tolerance and those with noninsulin dependent diabetes, but among those with diabetes, a larger effect was found in those with baseline HDL-c ≤35 mg/dL compared to higher levels.

#### Observational Studies, Intake

Twenty-one observational studies evaluated associations between total EPA+DHA±DPA intake (regardless of source) and numerous clinical outcomes. Only eight (38%) of these found significant associations with any clinical outcome.

By meta-analysis, overall there is a statistically significant association between marine oil intake and CVD death across a median dose range of 0.066 to 1.58 g/d (effect size per g/d = 0.88; 95% CI 0.82 to 0.95). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.2 g/d) consistently found a stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot closer to 1). This implies the possibility of a ceiling effect (where intake above a certain level adds no further benefit). However, at no dose threshold was there a statistically significant difference between the ES below the dose threshold (knot) and above the threshold. The best fit curve was found with a knot at 0.3 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at 0.2 g/d (P=0.26).

By meta-analysis, overall there no significant association between marine oil intake and CHD death across a median dose range of 0.04 to 2.1 g/d (effect size per g/d = 1.09; 95% CI 0.76 to 1.57). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.2 g/d) found stronger associations (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot closer to 1) for knots below 0.7 g/d, but stronger associations at higher doses above 0.7 g/d. However, the differences in effect size between lower and higher doses were always highly nonsignificant, implying no difference in association. The best fit curve was found with a knot at 0.5 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at the lowest tested threshold, 0.1 g/d (P=0.46).

By meta-analysis, overall there no significant association between marine oil intake and all-cause death across a median dose range of 0.066 to 1.58 g/d (effect size per g/d = 0.62; 95% CI 0.31 to 1.25). However, meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.2 g/d) consistently found stronger associations (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot closer to 1). This implies the possibility of a ceiling effect (where intake above a certain level adds no further benefit). For thresholds ≤0.4 g/d the associations are statistically significant at lower doses, but not statistically significant at higher doses. The difference between low- and high-dose associations is statistically significantly different at a threshold of 0.2 g/d (P=0.047). The best fit curve was found with a knot at 0.3 g/d. This analysis may suggest that marine oil intake above about 0.2 to 0.4 g/d may not further strengthen any association between higher marine oil intake and lower rate of all-cause death.

By meta-analysis, overall there no significant association between marine oil intake and CHD across a median dose range of 0.038 to 3.47 g/d (effect size per g/d = 0.94; 95% CI 0.81 to 1.10]). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.4 g/d) consistently found a stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1, ES above know about 1). At all knot points the differences were nonsignificant. This weakly suggests the possibility of a ceiling effect (where intake above a certain level adds no further benefit). The best fit curve was found with a knot at 0.4 g/d. The P values for differences between lower- and higher-dose knots were between 0.12 and 0.14 at all knots ≥0.3 g/d.

By meta-analysis, overall there is a statistically significant association between marine oil intake and total stroke across a median dosage range of 0.025 to 0.6 g/d (effect size per g/d = 0.68; 95% CI 0.53 to 0.87). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 0.5 g/d) consistently found a much stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below know less than 1; ES above know greater than 1); although, the difference in effect sizes above and below the knots were never statistically significant This implies a possible ceiling effect ceiling effect (where intake above a certain level adds no further benefit). However, given that the differences between lower and higher dose ES remained large across the range of testable dose thresholds, the actual ceiling dose threshold may be above the analyzable range (i.e., >0.5 g/d). The best fit curve was found with the lowest knot at 0.1 g/d. The P values for differences between lower- and higher-dose effect sizes ranged from 0.14 to 0.20.

By meta-analysis, overall there is a statistically significant association between higher marine oil intake and lower risk of ischemic stroke across a median dosage range of 0.025 to 0.6 g/d (effect size per g/d = 0.51; 95% CI 0.29 to 0.89). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 0.5 g/d) consistently found a much stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot near or greater than 1). All effect sizes below the knots were statistically significant and all above the knots were nonsignificant. The differences between lower- and higher-dose effect sizes were all statistically significant (P=0.03–0.049). This implies a ceiling effect (where intake above a certain level adds no further benefit). However, it is unclear what the threshold may be, as it may be greater than the highest threshold tested (0.4 g/d). The best fit curve was found with a knot at either 0.3 or 0.4 g/d. The difference between lower-dose and higher-dose ES estimates was statistically significant with a knot at 0.1 g/d.

By meta-analysis, overall there is no significant association between marine oil intake and hemorrhagic stroke across a median dosage range of 0.025 to 0.6 g/d (effect size per g/d = 0.61; 95% CI 0.34 to 1.11). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 0.5 g/d) consistently found similar associations above and below the knots. At no threshold was the difference in effect sizes statistically significant. The best fit curve was found with a knot at 0.1 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at 0.5 g/d (P=0.78).

By meta-analysis, overall there is a just-significant association between higher marine oil intake and decreased risk of CHF across a median dosage range of 0.014 to 0.71 g/d (effect size per g/d = 0.76; 95% CI 0.58 to 1.00). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 0.5 g/d) consistently found a stronger association (of higher dose being associated with lower risk) at lower doses than at higher doses (ES below knot less than 1; ES above knot closer to 1). This implies the possibility of a ceiling effect (where intake above a certain level adds no further benefit). However, given that the differences between lower and higher dose ES remained large across the range of testable dose thresholds, the actual ceiling dose threshold may be above the analyzable range (i.e., >0.5 g/d). At thresholds of 0.1 and 0.2 g/d, the difference in effect size at lower and higher doses were statistically significant (P values 0.04 and 0.03, respectively). But the most significant difference was found at the highest threshold tested, 0.5 g/d (P=0.02). The best fit curve was found with the lowest knot tested, 0.1 g/d.

A minority of studies found significant associations of decreased risk of other outcomes with increasing intake of EPA+DHA±DPA: MACE (1 of 2 studies), all-cause death (1 of 3 studies), CVD death (1 of 4 studies), CHD death (3 of 7 studies), MI (1 of 2 studies), incident CHF (1 of 5 studies), and AFib (1 of 3 studies). No studies found significant associations with cardiac death (1 study), total stroke death (1 study), ischemic stroke death (1 study), coronary revascularization (1 study), ventricular arrhythmia (1 study), SCD (2 studies), and incident hypertension (1 study). One study each analyzed MI death and ischemic stroke death and found a significant association.

#### Observational Studies, Biomarkers

Five studies evaluated combined EPA+DHA±DPA biomarkers, including adipose tissue, cholesteryl ester, erythrocyte, phospholipid, and plasma n-3 FA levels. Of the outcomes evaluated, none was analyzed by more than two studies. One study each found no significant association between various biomarker levels and MI, hemorrhagic stroke, total stroke (with a P value of 0.07), or cardiac death. One study found a significant association between higher phospholipid EPA+DHA+DPA and incident CHD. Another found a significant association between higher adipose EPA+DHA+DPA and acute coronary syndrome in men, but not in women. Two studies each evaluated CHF, ischemic stroke, and MACE. For each outcome only one of the studies found significant associations with EPA+DHA±DPA biomarker levels. In one of the studies of CHF, phospholipid EPA+DHA+DPA level was associated with the outcome in women only but cholesteryl ester EPA+DHA+DPA levels were not associated in either sex.

### EPA

For the most part, there is insufficient evidence regarding the effect of or association with EPA (specifically) and CVD clinical and intermediate outcomes (Table 49). There is low strength of evidence of no association between EPA intake and CHD and between EPA biomarkers and AFib; no RCTs evaluated these outcomes.

Table 49 Evidence profile for the effect and association of EPA, specifically, with CVD outcomes^*^

Outcome | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
Major adverse cardiovascular vents (MACE) | Insufficient | RCT: 1 Obs intake: 1 Obs biomarker: 3 | Low | RCT: NA Obs intake: NA Obs biomarker: Inconsistent All: Inconsistent | RCT: Precise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse RCT | RCT: Lower risk Obs intake: Lower risk Obs biomarker: Unclear
CVD death (including stroke) | Insufficient | RCT: 0 Obs intake: 2 Obs biomarker: 1 | Low | RCT: NA Obs intake: Inconsistent Obs biomarker: NA All: NA | RCT: NA Obs intake: Precise Obs biomarker: Precise | No RCT | RCT: NA Obs intake: Unclear Obs biomarker: Lower risk
Cardiac death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 1 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: Unclear | Sparse | RCT: NA Obs intake: NA Obs biomarker: No association
Coronary heart disease death | Insufficient | RCT: 1 Obs intake: 2 Obs biomarker: 1 | Low | RCT: NA Obs intake: Consistent Obs biomarker: NA All: Consistent | RCT: Imprecise Obs intake: Imprecise Obs biomarker: Imprecise | None | RCT: No effect Obs intake: No association Obs biomarker: No association
Myocardial infarction death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Heart failure death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Stroke death | Insufficient | RCT: 1 Obs intake: 1 Obs biomarker: 1 | Low | RCT: NA Obs intake: Obs biomarker: All: Consistent | RCT: Imprecise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse | RCT: No effect Obs intake: No association Obs biomarker: No association
Ischemic stroke death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: Precise Obs biomarker: NA | Sparse | RCT: NA Obs intake: Lower risk Obs biomarker: NA
Hemorrhagic stroke death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: NA | Sparse | RCT: NA Obs intake: No association Obs biomarker: NA
Death, all-cause | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 3 | Low | RCT: NA Obs intake: NA Obs biomarker: Inconsistent All: NA | RCT: Precise Obs intake: NA Obs biomarker: Precise | No RCT | RCT: No effect Obs intake: NA Obs biomarker: Unclear
Coronary heart disease | Low | RCT: 0 Obs intake: 2 Obs biomarker: 3 | Low | RCT: NA Obs intake: Yes Obs biomarker: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | No RCT | RCT: NA Obs intake: No association Obs biomarker: Unclear
Myocardial infarction | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 1 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: Precise | Sparse | RCT: No effect Obs intake: NA Obs biomarker: No association
Acute coronary syndrome | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 1 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | Sparse | RCT: NA Obs intake: No association Obs biomarker: No association
Angina pectoris | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 0 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Sparse | RCT: Lower risk Obs intake: NA Obs biomarker: NA
Atrial fibrillation | Low | RCT: 0 Obs intake: 0 Obs biomarker: 3 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: Imprecise | No RCT | RCT: NA Obs intake: NA Obs biomarker: No association
Ventricular Arrhythmia | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Congestive heart failure | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 3 | Low | RCT: NA Obs intake: NA Obs biomarker: Consistent All: NA | RCT: NA Obs intake: NA Obs biomarker: Precise | No RCT | RCT: NA Obs intake: NA Obs biomarker: Unclear
Stroke, total | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 1 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: Imprecise | Sparse | RCT: NA Obs intake: NA Obs biomarker: No association
Stroke, ischemic | Insufficient | RCT: 1 Obs intake: 1 Obs biomarkers: 2 | Low | RCT: NA Obs intake: NA Obs biomarkers: Consistent All: Consistent | RCT: Precise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse | RCT: No effect Obs intake: No association Obs biomarkers: No association
Stroke, hemorrhagic | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarkers: No association
Sudden cardiac death | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 1 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarkers: NA | No RCT | RCT: No effect Obs intake: NA Obs biomarkers: No association
Revascularization | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 0 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarker: NA
Hypertension | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Blood pressure (SBP, DBP, MAP combined) | Insufficient | RCT: 2 Obs intake: 0 Obs biomarker: 1 | NA | RCT: Inconsistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: Imprecise | Sparse | RCT: No effect Obs intake: NA Obs biomarker: Lower risk
LDL-c | Insufficient | RCT: 2 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarker: NA
HDL-c | Insufficient | RCT: 2 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarker: NA
Triglycerides | Insufficient | RCT: 2 Obs intake: 0 Obs biomarker: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Sparse | RCT: Lower risk (lower triglycerides) Obs intake: NA Obs biomarker: NA
HDL-c/Total cholesterol to LDL-c ratios | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 0 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Sparse | RCT: Lower risk Obs intake: NA Obs biomarker: NA

* No reporting bias was detected for any outcome. All studies that measured n-3 FA intake were assessed to be direct, while all biomarker studies were assessed to be indirect.

Abbreviations: CVD = cardiovascular disease, DBP = diastolic blood pressure, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MACE = major adverse cardiovascular events, MAP = mean arterial blood pressure, n-3 FA = omega-3 fatty acids, NA = not applicable, Obs = observational study, RCT = randomized controlled trial, SBP = systolic blood pressure, SoE = strength of evidence.

#### Clinical Event Outcomes, RCTs

Regarding clinical event outcomes, one trial in an at risk population (dyslipidemia), found that after 5 years, compared with placebo, people taking purified EPA 1.8 g/d had significantly lower risk of MACE and angina, but no significant difference in all-cause death, CHD death, coronary revascularization, SCD, or MI (also in the subgroup of people with prior CVD). Subgroup analysis for CHD death found no clear difference between those who also had CVD versus those without CVD.

#### Intermediate Outcomes, RCTs

One trial of purified EPA 3.8 g/d versus placebo found no significant effect on systolic BP, diastolic BP, or MAP. This trial and another of EPA 3.3 g/d found no significant effect of EPA on LDL-c or HDL-c. Both trials, however, found significant net reductions in Tg concentration (−42 and −23 mg/dL). The trial of EPA 3.8 g/d also found a significant reduction in Total:HDL-c ratio (−0.2).

#### Observational Studies, Intake

Eight studies evaluated associations between estimated total EPA intake (specifically) and clinical outcomes. No outcome was evaluated by more than two studies. One study each found no significant association between EPA intake and acute coronary syndrome, ischemic stroke, or total stroke death. One study found a significant association between higher EPA intake and lower ischemic stroke death in healthy adults (in quantiles with median EPA intake >0.07 g/d in men and >0.06 g/d in women), but no association with hemorrhagic stroke death. One study found a significant association between higher EPA intake and lower risk of all-cause death (>0.01 g/d) in healthy adults. Another study found a significant association with MACE in healthy adults (>0.09 g/d). Two studies, each, found no significant associations between EPA intake and incident CHD (although P=0.06 in one) or CHD death. For both incident hypertension and CVD death, one of two studies found significant associations between higher EPA (0.02 g/d for hypertension and 0.01 g/d for CVD death) intake and lower risk of outcomes; the other studies found no such associations.

#### Observational Studies, Biomarkers

Ten studies evaluated associations between various EPA biomarkers and clinical outcomes. For three clinical outcomes, two of three studies found significant associations between higher EPA biomarker level and reduced risk of outcome. Three studies of healthy adults evaluated CHD, two of which found increased plasma or phospholipid EPA levels were associated with reduced CHD risk; the third study evaluated blood EPA levels. Three studies, two in healthy adults, one in people with hypercholesterolemia, evaluated MACE; the study of people with hypercholesterolemia found an association of reduced MACE risk with higher plasma EPA, as did one study of phospholipid EPA in healthy adults. The third study found no significant association between erythrocyte EPA and MACE in healthy adults. Three studies, two in healthy adults, one in adults with a history of MI, evaluated CHF; in one study of healthy adults higher plasma EPA was associated with reduced CHF risk, but the other study of healthy adults found no association with phospholipid or cholesteryl ester EPA. The study in people with a history of MI also found an association with higher blood EPA. In this latter study, significant interactions were found for sex (no association was seen in women, in contrast with a significant association in men), statin use (those on statins had no association, in contrast with those on statins), and baseline HDL-c level (those with higher HDL-c had no association, in contrast with those with HDL-c <40 mg/dL). No interactions were found for age, use of angiotensin receptor blocker drugs, use of beta blocker drugs, diabetes, dyslipidemia, baseline LDL-c, hypertension, glomerular filtration function, or hypertriglyceridemia.

One of three studies found a significant association between higher EPA biomarkers (plasma EPA) and lower risk of death in healthy adults, but a second study of plasma EPA in healthy adults found no such association; nor did a study of blood EPA in people with a history of MI. One of two studies of plasma EPA in healthy adults found a significant association with CVD death. Two studies found no significant association between EPA biomarkers and ischemic stroke. One study found a significant association between erythrocyte EPA and incident hypertension. One study each found no associations between EPA biomarker levels and acute coronary syndrome, AFib, SCD, MI, hemorrhagic stroke, total stroke, cardiac death, CHD death, or total stroke death.

### DHA

For the most part, there is insufficient evidence regarding the effect of or association with EPA (specifically) and CVD clinical and intermediate outcomes (Table 50). There is moderate strength of evidence of no effect of purified DHA supplementation on BP or LDL-c and low strength of evidence of no association between DHA intake and incident CHD (from observational studies only).

Table 50 Evidence profile for the effect and association of DHA, specifically, with CVD outcomes^*^

Outcome | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
Major adverse cardiovascular events (MACE) | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 4 | Low | RCT: NA Obs intake: NA Obs biomarker: Inconsistent All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | No RCT | RCT: NA Obs intake: Unclear Obs biomarker: Unclear
CVD death (including stroke) | Insufficient | RCT: 0 Obs intake: 2 Obs biomarker: 1 | Low | RCT: NA Obs intake: Consistent Obs biomarker: NA All: NA | RCT: NA Obs intake: Precise Obs biomarker: Precise | No RCT | RCT: NA Obs: Unclear Obs biomarker: Lower risk
Cardiac death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 1 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: Unclear | Sparse | RCT: NA Obs intake: NA Obs biomarker: No association
Coronary heart disease death | Insufficient | RCT: 0 Obs intake: 2 Obs biomarker: 1 | Low | RCT: NA Obs intake: Consistent Obs biomarker: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Precise | No RCT | RCT: NA Obs intake: No association Obs biomarker: Lower risk
Myocardial infarction death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Heart failure death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Stroke death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 1 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | Sparse | RCT: NA Obs intake: No association Obs biomarker: Unclear
Ischemic stroke death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: Precise Obs biomarker: NA | Sparse | RCT: NA Obs intake: Lower risk Obs biomarker: NA
Hemorrhagic stroke death | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 0 | Moderate | RCT: NA Obs intake: NA Obs biomarker: All: | RCT: NA Obs intake: Imprecise Obs biomarker: NA | Sparse | RCT: NA Obs intake: No association Obs biomarker: NA
Death, all-cause | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 3 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: Precise | No RCT | RCT: NA Obs intake: NA Obs biomarker: Unclear
Coronary heart disease | Low | RCT: 0 Obs intake: 2 Obs biomarker: 3 | Low | RCT: NA Obs intake: Yes Obs biomarker: Inconsistent All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | No RCT | RCT: NA Obs intake: No association Obs biomarker: Unclear
Myocardial infarction | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 0 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: Unclear Obs biomarker: NA | Sparse | RCT: NA Obs intake: No association Obs biomarker: NA
Acute coronary syndrome | Insufficient | RCT: 0 Obs intake: 1 Obs biomarker: 1 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | Sparse | RCT: NA Obs intake: No association Obs biomarker: NA
Angina pectoris | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Atrial fibrillation | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 1 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: Precise | Sparse | RCT: NA Obs intake: NA Obs biomarker: Lower risk
Ventricular Arrhythmia | Insufficient | RCT: 0 Obs intake: 0 Obs biomarkers: 0 | NA | RCT: NA Obs intake: NA Obs biomarkers: NA | RCT: NA Obs intake: NA Obs biomarkers: NA | No data | RCT: NA Obs intake: NA Obs biomarkers: NA
Congestive heart failure | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 3 | NA | RCT: NA Obs intake: NA Obs biomarker: Consistent All: NA | RCT: NA Obs intake: NA Obs biomarker: Imprecise | No RCT | RCT: NA Obs intake: NA Obs biomarker: Unclear
Stroke incidence and death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 1 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: Imprecise | Sparse | RCT: NA Obs intake: NA Obs biomarker: No association
Ventricular arrhythmia | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Revascularization | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Hypertension | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Blood pressure (SBP, DBP, MAP combined) | Moderate | RCT: 3 Obs intake: 0 Obs biomarker: 1 | NA | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: Imprecise | Few studies | RCT: No effect Obs intake: NA Obs biomarker: Lower risk
LDL-c | Moderate | RCT: 3 Obs intake: 0 Obs biomarker: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Few studies | RCT: No effect Obs intake: NA Obs biomarker: NA
HDL-c | Insufficient | RCT: 3 Obs intake: 0 Obs biomarker: 0 | Low | RCT: Inconsistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Few studies | RCT: Unclear Obs intake: NA Obs biomarker: NA
Triglycerides | Insufficient | RCT: 2 Obs intake: 0 Obs biomarker: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Sparse | RCT: Lower risk (lower triglycerides) Obs intake: NA Obs biomarker: NA
HDL-c/Total cholesterol to LDL-c ratios | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA

* No reporting bias was detected for any outcome. All studies that measured n-3 FA intake were assessed to be direct, while all biomarker studies were assessed to be indirect.

Abbreviations: CVD = cardiovascular disease, DBP = diastolic blood pressure, DHA = docosahexaenoic acid, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MAP = mean arterial blood pressure, n-3 FA = omega-3 fatty acids, NA = not applicable, Obs = observational study, RCT = randomized controlled trial, SBP = systolic blood pressure, SoE = strength of evidence.

#### Clinical Event Outcomes, RCTs

No trial that reported clinical event outcomes evaluated DHA alone.

#### Intermediate Outcomes, RCTs

Two trials compared purified DHA (3.6 and 2 g/d) to placebo and found no significant effects on systolic or diastolic BP. One of the trials also found no significant effect on MAP. Three trials of DHA (3.7, 3.6, or 2 g/d) also found no significant effect compared to placebo on LDL-c or HDL-c. Two of the trials (3.7 and 3.6 g/d) reported on Tg concentration changes and both found significant net reductions compared to placebo with DHA supplementation (−27 and −29 mg/dL). The trial of DHA 3.6 g/d also found a significant reduction in Total:HDL-c ratio (−0.3).

#### Observational Studies, Intake

Eight studies evaluated the association between estimated total DHA intake (specifically) and risk of clinical outcomes. No study evaluated any outcome in more than two studies. Two studies found significant associations between higher DHA intake and lower risk of incident hypertension in healthy young adults (18–30 years old in one study; 39–54 year old women in a subgroup of one study), but not in an older subgroup in one study (55–89 years old). In the study of young adults, a significant association was found in quartiles with DHA intake >0.06 g/d. One of two studies of healthy adults found an association of lower CVD death with DHA intake >0.15 g/d. Two studies each found no association with CHD death or incident CHD (in populations with a broad range of ages, from 20–69 to 45–84 years old). One study each found significant associations of higher DHA intake with MACE (>0.15 g/d DHA), ischemic stroke death (>0.15 g/d), and all-cause death (>0.02 g/d). In one study each, no associations were found with acute coronary syndrome, ischemic stroke, hemorrhagic stroke death, or total stroke death.

#### Observational Studies, Biomarkers

Eleven studies evaluated various DHA biomarkers and their associations with clinical outcomes. A high proportion of association analyses were statistically significant favoring higher DHA biomarker levels. Four studies evaluated MACE (with various definitions); two found significant associations between higher DHA biomarker levels (phospholipid and adipose DHA) and lower risk of MACE in healthy adults. The other two studies found no association, one in hypercholesterolemic adults on statins (plasma DHA) and one in healthy adults (erythrocyte DHA). Two of three studies in healthy adults found significant associations between lower CHD risk and higher plasma or phospholipid DHA; the third study, also in healthy adults found no association with blood DHA. Three studies evaluated CHF. One found associations between higher cholesteryl ester and phospholipid DHA and lower risk of incident CHF in healthy women, but not healthy men (whether the associations were significantly different between women and men was not reported). One study found that overall, there was no significant association with blood DHA in adults with a history of MI, but that there were significant associations in subgroups of people (where the difference in association between subgroups was at least nearly significant [P<0.10]), such that significant association were found in people (after MI) not taking a statin (P interaction with statin use = 0.003), ≥65 years old (P interaction = 0.051), with LDL-c ≥100 mg/dL (P interaction = 0.068), and with HDL-c ≤40 mg/dL (P interaction = 0.096). Three studies also evaluated all-cause death, two of which found significantly lower risk of death with higher plasma DHA (healthy adults) and blood DHA (in people with a history of MI who were not taking statins); another study of healthy adults found no association with plasma DHA.

Two studies found nonsignificant associations between higher cholesteryl ester DHA (P=0.07), phospholipid DHA (P=0.08), and plasma DHA (P=0.052) and lower risk of ischemic stroke in healthy adults. One study of healthy adults found an association between higher plasma DHA and lower risk of CVD death (both studies evaluated plasma DHA). One study each found significant associations between higher DHA biomarker levels and lower incidence of AFib, SCD, and CHD death (all plasma DHA in healthy adults). One study found a significant association between higher adipose DHA and lower risk of acute coronary syndrome in healthy men, but not healthy women. Another study found a significant association between higher erythrocyte DHA and lower risk of incident hypertension in healthy women aged 39 to 54 years, but not in women older than 54 years. One study found no significant associations between plasma DHA and both total stroke and total stroke death in healthy adults. One study, each, found no significant associations with MI, hemorrhagic stroke, or cardiac death.

### DPA

Overall, there is insufficient evidence regarding effect of or association between DPA (specifically) and CVD clinical and intermediate outcomes (Table 51). There is low strength of evidence of no association between DPA biomarker levels and risk of AFib (from observational studies only).

Table 51 Evidence profile for the effect and association of DPA biomarkers, specifically, with CVD outcomes (observational studies only)^*^

Outcome | SoE Grade | Biomarker Studies No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
MACE | Insufficient | 3 | Low | Inconsistent | Imprecise | None | Unclear
CVD death (including stroke) | Insufficient | 1 | Low | | Imprecise | None | Lower risk
Cardiac death | Insufficient | 1 | Low | | Unclear | None | No association
Coronary heart disease death | Insufficient | 1 | Low | | Imprecise | None | No association
Myocardial infarction death | Insufficient | 0 | NA | | NA | None | NA
Heart failure death | Insufficient | 0 | NA | | NA | None | NA
Stroke death | Insufficient | 1 | Low | | Imprecise | None | Lower risk
Ischemic stroke death | Insufficient | 0 | NA | | NA | None | NA
Hemorrhagic stroke death | Insufficient | 0 | NA | | NA | None | NA
Death, all-cause | Insufficient | 1 | Low | | Precise | None | Lower risk
Coronary heart disease | Insufficient | 3 | Low | Inconsistent | Imprecise | None | Unclear
Myocardial infarction | Insufficient | 0 | NA | | NA | None | NA
Acute coronary syndrome | Insufficient | 1 | Low | NA | Imprecise | Sparse | No association
Angina pectoris | Insufficient | 0 | NA | NA | NA | NA | NA
Atrial fibrillation | Low | 3 | Low | Consistent | Imprecise | None | No association
Congestive heart failure | Insufficient | 1 | Low | NA | Imprecise | Sparse | Lower risk
Stroke incidence and death | Insufficient | 1 | Low | NA | Precise | Sparse | No association
Ventricular arrhythmia | Insufficient | 0 | NA | NA | NA | NA | NA
Revascularization | Insufficient | 0 | NA | NA | NA | None | NA
Hypertension | Insufficient | 0 | NA | NA | NA | None | NA
Blood pressure (SBP, DBP, MAP combined) | Insufficient | 1 | Low | NA | Imprecise | Sparse | Lower risk
LDL-c | Insufficient | 0 | NA | NA | NA | None | NA
HDL-c | Insufficient | 0 | NA | NA | NA | None | NA
Triglycerides | Insufficient | 0 | NA | NA | NA | None | NA
HDL-c/Total cholesterol to LDL-c ratios | Insufficient | 0 | NA | NA | NA | None | NA

* No reporting bias was detected for any outcome. All studies that measured n-3 FA intake were assessed to be direct, while all biomarker studies were assessed to be indirect.

Abbreviations: CVD = cardiovascular disease, DBP = diastolic blood pressure, DPA = docosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MACE = major adverse cardiovascular events, MAP = mean arterial blood pressure, n-3 FA = omega-3 fatty acids, NA = not applicable, Obs = observational study, RCT = randomized controlled trial, SBP = systolic blood pressure, SoE = strength of evidence.

#### RCTs

No eligible RCTs compared purified DPA formulations versus placebo.

#### Observational Studies, Intake

Two observational studies evaluated estimated total DPA intake (specifically). One study found no significant association between DPA intake and acute coronary syndrome in either healthy men or women. The other found significant associations between higher DPA intake and both incident CHD and MACE in healthy adults, in both instances with a significant association in the quartile with DPA intake >0.04 g/d.

#### Observational Studies, Biomarkers

Seven studies evaluated the association of various DPA biomarkers with clinical outcomes, all in healthy adults. No outcome was evaluated by more than three studies. One study in adults age ≥65 years was the only study that evaluated several clinical outcomes. It found significant associations between higher plasma DPA and lower risks of all-cause and CVD death, nonsignificant associations with incident CHF (P=0.057) and total stroke death (P=0.056), but no significant associations with AFib, SCD, hemorrhagic, ischemic, or total stroke, or CHD death. For two outcomes, one of three studies found significant associations; one study found a significant association between blood DPA and incident CHD, but two found no associations with plasma or phospholipid DPA; one study found a significant association between adipose tissue DPA and MACE, but two found no associations with phospholipid or erythrocyte DPA. One study evaluated acute coronary syndrome and found a significant association in men with adipose tissue DPA, but not in women. One study evaluated incident hypertension and found a significant association of erythrocyte DPA in younger women (39–54 years old), but not older women (55–89 years old). One study found no significant association with cardiac death.

### SDA

Overall, there is insufficient evidence regarding effect of or association between SDA (specifically) and CVD clinical and intermediate outcomes (Table 52).

Table 52 Evidence profile for the effect and association of SDA biomarkers, specifically, with CVD outcomes (observational studies only)^*^

Outcome | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
MACE | Insufficient | 1 | Low | NA | Obs biomarker: Unclear | Sparse | No association
CVD death (including stroke) | Insufficient | 0 | NA | NA | NA | No data | NA
Cardiac death | Insufficient | 1 | Low | NA | Obs biomarker: Unclear | Sparse | No association
Coronary heart disease death | Insufficient | 0 | NA | NA | NA | No data | NA
Myocardial infarction death | Insufficient | 0 | NA | NA | NA | No data | NA
Heart failure death | Insufficient | 0 | NA | NA | NA | No data | NA
Stroke death | Insufficient | 0 | NA | NA | NA | No data | NA
Ischemic stroke death | Insufficient | 0 | NA | NA | NA | No data | NA
Hemorrhagic stroke death | Insufficient | 0 | NA | NA | NA | No data | NA
Death, all-cause | Insufficient | 0 | NA | NA | NA | No data | NA
Coronary heart disease | Insufficient | 0 | NA | NA | NA | No data | NA
Myocardial infarction | Insufficient | 0 | NA | NA | NA | No data | NA
Acute coronary syndrome | Insufficient | 0 | NA | NA | NA | No data | NA
Angina pectoris | Insufficient | 0 | NA | NA | NA | No data | NA
Atrial fibrillation | Insufficient | 0 | NA | NA | NA | No data | NA
Ventricular Arrhythmia | Insufficient | 0 | NA | NA | NA | No data | NA
Congestive heart failure | Insufficient | 0 | NA | NA | NA | No data | NA
Stroke incidence and death | Insufficient | 0 | NA | NA | NA | No data | NA
Ventricular arrhythmia | Insufficient | 0 | NA | NA | NA | No data | NA
Revascularization | Insufficient | 0 | NA | NA | NA | No data | NA
Hypertension | Insufficient | 0 | NA | NA | NA | No data | NA
Blood pressure (SBP, DBP, MAP combined) | Insufficient | 1 | Low | NA | Precise | Sparse | No effect
LDL-c | Insufficient | 1 | Low | NA | Precise | Sparse | No effect
HDL-c | Insufficient | 1 | Low | NA | Precise | Sparse | No effect
Triglycerides | Insufficient | 1 | Low | NA | Precise | Sparse | No effect
HDL-c/Total cholesterol to LDL-c ratios | Insufficient | 1 | Low | NA | Precise | Sparse | No effect

* No reporting bias was detected for any outcome. All studies that measured n-3 FA intake were assessed to be direct, while all biomarker studies were assessed to be indirect.

Abbreviations: CVD = cardiovascular disease, DBP = diastolic blood pressure, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MACE = major adverse cardiovascular events, MAP = mean arterial blood pressure, n-3 FA = omega-3 fatty acids, NA = not applicable, Obs = observational study, RCT = randomized controlled trial, SBP = systolic blood pressure, SDA = stearidonic acid, SoE = strength of evidence.

#### RCTs

A single study compared 1.2 g/d SDA to placebo in patients at risk for CVD and found no significant differences in change in systolic or diastolic BP, or LDL-c, HDL-c, or Tg at 6 weeks.

#### Observational Studies

A single eligible observational study in healthy men evaluated baseline erythrocyte SDA and clinical outcomes. Erythrocyte SDA was not significantly associated with either MACE or cardiac death.

### Marine Oil FA Comparisons

There is insufficient evidence regarding comparisons of specific marine oil FA.

#### Clinical Event Outcomes, RCTs

No trial that reported clinical event outcomes compared marine oil FA.

#### Intermediate Outcomes, RCTs

Two trials that compared marine oil FA (EPA 3.8 g/d vs. DHA 3.6 g/d; EPA+DHA 3.4 and 1.7 g/d vs. EPA 1.8 g/d) found no significant differences in effect on BP, LDL-c, HDL-c, Tg, or Total:HDL-c ratio.

One trial compared 2.0 g/d SDA and 1.9 g/d EPA+DHA+DPA in healthy people. At 2 month followup, no significant differences in change in systolic or diastolic BP, or LDL-c, HDL-c, Tg, Total:HDL-c, or LDL:HDL-c ratios were found.

### ALA

There is moderate strength of evidence of no significant effect of ALA intake on BP, LDL-c, HDL-c, or Tg (Table 53). There is low strength of evidence of no association between ALA intake or biomarker level and CHD or CHD death, AFib, and CHF, each based primarily on observational studies; there was only a single or no RCTs evaluating these outcomes. There is insufficient evidence regarding other outcomes.

Table 53 Evidence profile for the effect and association of ALA with CVD outcomes^*^

Outcome | SoE Grade | Design No. Studies | Study Limitations | Consistency | Precision | Other Issues | Finding
Major adverse cardiovascular events (MACE) | Insufficient | RCT: 1 Obs intake: 2 Obs biomarker: 0 | Low | RCT: NA Obs intake: Consistent Obs biomarker: All: NA | RCT: Precise Obs intake: Imprecise Obs biomarker: NA | Sparse | RCT: NA Obs intake: 0 Obs biomarker: NA
CVD death (including stroke) | Insufficient | RCT: 1 Obs intake: 3 Obs biomarker: 2 | Low | RCT: NA Obs intake: Inconsistent Obs biomarker: Consistent All: NA | RCT: Imprecise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse RCT | RCT: No effect Obs intake: Unclear Obs biomarker: No association
Cardiac death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 1 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: NA Obs intake: NA Obs biomarker: Unclear | Sparse | RCT: NA Obs intake: NA Obs biomarker: No association
Coronary heart disease death | Low | RCT: 1 Obs intake: 4 Obs biomarker: 1 | Low | RCT: NA Obs intake: Consistent Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse RCT | RCT: No effect Obs intake: No association 0.94 (0.85, 1.03) per g/d Obs biomarker: No association
Myocardial infarction death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Heart failure death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Stroke death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Ischemic stroke death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Hemorrhagic stroke death | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Death, all-cause | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 2 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: Precise | Sparse | RCT: No effect Obs intake: NA Obs biomarker: No association
Coronary heart disease | Low | RCT: 0 Obs intake: 6 Obs biomarker: 0 | Low | RCT: NA Obs intake: Yes Obs biomarker: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: NA | No RCT | RCT: NA Obs intake: No association 0.97 (0.92, 1.03) per g/d Obs biomarker: NA
Myocardial infarction | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 0 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: Unclear Obs intake: NA Obs biomarker: NA
Acute coronary syndrome | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Angina pectoris | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 0 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarker: NA
Atrial fibrillation | Low | RCT: 0 Obs intake: 3 Obs biomarker: 3 | Low | RCT: NA Obs intake: Consistent Obs biomarker: NA All: NA | RCT: NA Obs intake: Imprecise Obs biomarker: Imprecise | No RCT | RCT: NA Obs intake: No association Obs biomarker: No association
Ventricular Arrhythmia | Insufficient | RCT: 1 Obs intake: 0 Obs biomarkers: 0 | Low | RCT: NA Obs intake: NA Obs biomarkers: NA | RCT: Precise Obs intake: NA Obs biomarkers: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarkers: NA
Congestive heart failure | Low | RCT: 1 Obs intake: 4 Obs biomarker: 3 | Low | RCT: NA Obs intake: Consistent Obs biomarker: Consistent All: Consistent | RCT: Imprecise Obs intake: Precise Obs biomarker: Precise | Sparse RCT | RCT: No effect Obs: No association Obs biomarker: Unclear
Stroke incidence and death | Insufficient | RCT: 1 Obs intake: 3 Obs biomarker: 2 | Low | RCT: NA Obs intake: Consistent Obs biomarker: Consistent All: Consistent | RCT: Imprecise Obs intake: Imprecise Obs biomarker: Imprecise | Sparse RCT | RCT: No effect Obs intake: Unclear Obs biomarker: No association
Ventricular arrhythmia | Insufficient | RCT: 1 Obs intake: 0 Obs biomarker: 0 | Low | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarker: NA
Revascularization | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Hypertension | Insufficient | RCT: 0 Obs intake: 0 Obs biomarker: 0 | NA | RCT: NA Obs intake: NA Obs biomarker: NA All: NA | NA | No data | RCT: NA Obs intake: NA Obs biomarker: NA
Blood pressure (SBP, DBP, MAP combined) | Moderate | RCT: 5 Obs intake: 0 Obs biomarker: 1 | Low | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: Imprecise | Few studies | RCT: No effect Obs intake: NA Obs biomarker: No association
LDL-c | Moderate | RCT: 5 Obs intake: 0 Obs biomarker: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarker: NA
HDL-c | Moderate | RCT: 5 Obs intake: 0 Obs biomarker: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Few studies | RCT: No effect Obs intake: NA Obs biomarker: NA
Triglycerides | Moderate | RCT: 5 Obs intake: 0 Obs biomarker: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Imprecise Obs intake: NA Obs biomarker: NA | No data | RCT: No effect Obs intake: NA Obs biomarker: NA
HDL-c/Total cholesterol to LDL-c ratios | Insufficient | RCT: 3 Obs intake: 0 Obs biomarker: 0 | Low | RCT: Consistent Obs intake: NA Obs biomarker: NA All: NA | RCT: Precise Obs intake: NA Obs biomarker: NA | Sparse | RCT: No effect Obs intake: NA Obs biomarker: NA

* No reporting bias was detected for any outcome. All studies that measured n-3 FA intake were assessed to be direct, while all biomarker studies were assessed to be indirect.

Abbreviations: ALA = alphalinolenic acid, CVD = cardiovascular disease, DBP = diastolic blood pressure, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MAP = mean arterial blood pressure, n-3 FA = omega-3 fatty acids, NA = not applicable, Obs = observational study, RCT = randomized controlled trial, SBP = systolic blood pressure, SoE = strength of evidence.

#### Clinical Event Outcomes, RCTs

Two RCTs that evaluated ALA supplementation versus placebo reported clinical event outcomes, one in participants with CVD and one in healthy participants. All analyses were nonsignificant, for all-cause death (2 trials) and from one trial each, MACE, CVD death, cardiac death, CHD death, CHF death, total MI, incident angina, total stroke, ventricular arrhythmia, and SCD. Within-study subgroup analyses revealed no significant differences in effect for various subgroups for MACE (1 trial) or with or without diabetes for CHD death (1 trial).

#### Intermediate Outcomes, RCTs

Five ALA RCTs evaluated BP, with doses ranging from 1.4 to 5.9 g/d for 1 to 3.4 years. All found no significant effect on systolic or diastolic BP, mostly with wide confidence intervals. One of the trials found no significant difference in effect on BP between those with hypertension and the study population as a whole. Another trial found no significant difference in effect between 1.4 and 5.9 g/d ALA. No trial reported on MAP.

Five trials reported no significant effects of ALA on LDL-c, HDL-c, Tg, or Total:HDL-c ratio (3 trials). No differences in effect were found in the one trial that compared 1.4 and 5.9 g/d ALA. No trial reported on LDL:HDL-c ratio.

#### Observational Studies, Intake

Thirteen observational studies evaluated ALA intake. One of these was a pooling of 11 prior studies (the pooled studies were not included in duplicate for the outcomes evaluated by the pooling study). The large majority of analyses found no significant associations; only two studies found any significant associations between higher ALA intake and clinical outcomes.

By meta-analysis, overall there is no statistically significant association between ALA intake and CHD death across a median dose range of 0.59 to 2.5 g/d (effect size per g/d = 0.95 [95% CI 0.87 to 1.04]). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.1 to 1.2 g/d) consistently found a stronger association (of higher dose being associated with lower risk at higher doses than at lower doses (ES above knot < ES below know), but at several knot points this difference was marginal. This implies the possibility of a floor effect (where intake above a certain minimum amount is needed before any benefit accrues). However, at no dose threshold was there a statistically significant difference between the ES above the dose threshold (knot) and below the threshold. The best fit curve was found with a knot at 0.9 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at 1.2 g/d (P=0.41), the highest dose threshold that could be tested.

By meta-analysis, overall there is no association between ALA intake and CHD across a median dosage range of 0.2 to 2.5 g/d (effect size per g/d = 0.98 [95% CI 0.93 to 1.04]). Meta-analyses with the addition of a spline knot point at different dose thresholds (from 0.5 to 1.4 g/d) consistently found marginally smaller ES at lower doses than at higher doses. At no dose threshold was there a statistically significant difference between the ES below the dose threshold (knot) and above the threshold. The best fit curve was found with a knot at 0.6 g/d. The lowest P value between lower-dose and higher-dose ES estimates was found at 0.5 g/d (P=0.28).

Two studies both found significant associations between higher ALA intake and reduced all-cause death (>2.2 g/d in healthy adults; also in healthy men but insufficient data were reported regarding a dose threshold). One of two studies found a significant association between higher ALA intake (>0.6 g/d) and lower risk of SCD in healthy women but not in a subset of women with CVD; the second study found no significant association in healthy adults. One of two studies found a significant association between higher ALA intake (unclear threshold) and lower risk of CVD death in younger men (35–57 years old), but another study found no association in older men (≥65 years old). For all other analyzed clinical outcomes, no significant associations were found with ALA intake, including CHF (4 studies), CVD (3 studies), MACE (2 studies), hemorrhagic and ischemic stroke (2 studies each), AFib (1 study), and hypertension (1 study).

#### Observational Studies, Biomarkers

Eight studies evaluated various ALA biomarkers. Almost all analyses found no significant associations between ALA biomarkers and clinical outcomes. No outcome was evaluated by more than three studies. For CHF, one of three studies found a significant association between higher plasma ALA in healthy men, but two other studies found no significant associations in healthy adults with plasma, cholesteryl ester, or phospholipid ALA. One of two studies found a significant association between higher plasma ALA and lower risk of CVD death, but the other study found no significant association also with plasma ALA in healthy adults. No significant associations were found for ischemic stroke (3 studies), incident CHD, hemorrhagic and total stroke (2 studies each), MACE (2 studies), all-cause death (2 studies), or AFib, SCD, incident hypertension, cardiac death, or CHD death (1 study each).

### Marine Oil Versus ALA

There is insufficient evidence of direct comparisons between marine oil and ALA intake on CVD outcomes. Across studies, the comparison between marine oil and ALA is unclear, largely because of insufficient evidence regarding ALA; however, where there is high strength of evidence of significant effects of marine oil on improving Tg and HDL-c, there is moderate strength of evidence of no effect of ALA intake on these intermediate outcomes.

#### Clinical Event Outcomes, RCTs

No trial that reported clinical event outcomes directly compared marine oils and ALA.

#### Intermediate Outcomes, RCTs

One trial that compared two doses of EPA+DHA (1.7 and 0.8 g/d) with ALA 4.5 g/d found no differences in systolic or diastolic BP at 4 months. Across trials, regardless of n-3 FA type, there was no evidence of an effect of BP; no difference in effect was apparent between marine oil and ALA trials.

Two trials that compared EPA+DHA (0.8 and 1.7 g/d in one trial, 0.4 g/d in the other) to ALA (4.5 [rapeseed oil margarine] and 2 g/d [“plant oil” margarine], respectively) for 6 months and 3.4 years found no differences between n-3 FA types for LDL-c, HDL-c, or Tg. Neither trial reported on lipid ratios. No evident differences were found across trials between marine oils and ALA for their (nonsignificant) effects on LDL-c and HDL-c. In contrast with the two trials that directly compared EPA+DHA and ALA, 32 marine oil (versus placebo) trials fairly consistently found significant effect on Tg reduction in contrast with the four ALA (versus placebo) trials, which mostly had imprecise estimates of effects on Tg.

## Subgroup Analyses Summary

Overall, 24 RCTs46, 58, 70, 76, 85, 89, 90, 94, 96, 97, 99, 115, 119, 123, 128, 146, 147, 150, 156, 157, 160, 166, 167, 179, 195 and 9 observational studies72, 83, 102, 148, 154, 159, 162, 171, 181 reported on subgroup (or factorial) analyses. For most outcomes, there is insufficient evidence regarding differential effects (or associations) in different subgroups of study participants evaluated within studies. Metaregression results across studies are summarized in the summary by n-3 FA, above. (In brief, only for the effect of marine oil on Tg was there an indication across studies of interactions by dose and baseline Tg, with larger effects with higher dose and higher baseline Tg.) Among outcomes with sufficient RCT data to allow meta-analysis, no discernable difference in effect was found across trials based on publication year.

Twenty-two subgroup analyses by sex were reported (10 with ALA, 11 with marine oil, 1 with total n-3 FA). One of three RCTs of marine oil on MACE found a greater beneficial effect of n-3 FA in women (HR [supplement vs. placebo] =0.82 in women vs. 1.04 in men; P interaction = 0.04). One of three observational studies of CHF found a stronger association with between higher blood EPA and lower risk of CHF in men than women (HR [lower intake vs. higher intake] = 5.82 in men vs. 0.69 in women; P interaction = 0.008), but no interaction with blood DHA. One RCT found a stronger effect on lowering Tg of supplementation with higher-dose marine oil (1.8 g/d) in men than in women (difference not reported; P interaction = 0.038), but this interaction was not found with lower-dose marine oil (0.7 g/d). All 19 other analyses were not statistically significant (or no statistical difference was reported).

Twenty subgroup analyses by statin use were reported (1 with ALA, 19 with marine oil). All but one study found difference in effect or association based on statin use. One study found a stronger association between higher blood DHA and, separately, higher blood EPA, and lower risk of CHF in those not using statins; DHA: HR [lower intake vs. higher intake] = 6.65 (without statins) vs. 0.74 (with statins), P interaction = 0.003; EPA: HR [lower intake vs. higher intake] = 6.40 (without statins) vs. 1.45 (with statins), P interaction = 0.048. A relatively small number of RCTs of lipoproteins (LDL-c and HDL-c) and Tg analyzed interactions between n-3 FA and statins and found no interaction between statin use and the effect of marine oil supplementation on lipids (LDL-c 5 RCTs, Tg 4 RCTs, HDL-c 3 RCTs). No studies explicitly compared the interaction of n-3 FA intake (or biomarker level) with aspirin intake on outcomes.

Sixteen subgroup analyses comparing those with and without diabetes were reported (6 with ALA, 10 with marine oil). Two RCT analyses reported only that a statistically significant effect of n-3 FA was found among participants with diabetes but no significant effect was found those without diabetes (marine oil and CHD death, ALA and ventricular arrhythmia). All other analyses reported no difference in effect or association based on diabetes status.

## Summary by Key Question

### Key Question 1

What is the efficacy or association of n-3 FA (EPA, DHA, EPA+DHA, DPA, SDA, ALA, or total n-3 FA) exposures in reducing CVD outcomes (incident CVD events, including all-cause death, CVD death, nonfatal CVD events, new diagnosis of CVD, peripheral vascular disease, CHF, major arrhythmias, and hypertension diagnosis) and specific CVD risk factors (BP, key plasma lipids)?

- Total n-3 FA
  ○ Overall, there is insufficient evidence regarding the effect of or association between total n-3 FA (combined ALA and marine oils) and clinical or intermediate outcomes. There is low strength of evidence of no association between total n-3 FA intake and stroke death, and total (fatal and nonfatal) MI (each association based on longitudinal observational studies of dietary intake).
  ○ For each outcome there was no consistent (and replicated) significant association between total n-3 FA intake and risk reduction.
- Marine oils
  ○ There is high strength of evidence from RCTs that marine oils clinically and statistically significantly lower Tg. There is also evidence that they statistically, but arguably not clinically, significantly raise HDL-c, but lower LDL-c. Finally, there is high strength of evidence that marine oil supplementation significantly lowers Total:HDL-c ratio.
  ○ There is high strength of evidence of that marine oils statistically significantly lower Tg—possibly with greater effects with higher doses and in people with higher baseline Tg—and statistically significantly raise HDL-c and LDL-c by similar amounts. There is also high strength of evidence that marine oil significantly lowers Total:HDL-c ratio
  ○ There is low strength of evidence that marine oil significantly lowers risk of ischemic stroke.
  ○ There is a high strength of evidence of no effect of marine oil on risk of MACE, all-cause death, SCD, revascularization, and BP; moderate strength of evidence of no effect of marine oil on risk of AFib; and low strength of evidence of no effect of marine oil on risk of CVD death, CHD death, total CHD, MI, angina pectoris, CHF, total stroke, and hemorrhagic stroke. There is insufficient evidence for other outcomes.
- Marine oils, EPA
  ○ There is insufficient evidence regarding the effect of or association with EPA (specifically) and most CVD clinical and intermediate outcomes. There is low strength of evidence of no association between EPA intake and CHD and between EPA biomarkers and AFib.
- Marine oils, DHA
  ○ For the most part, there is insufficient evidence regarding the effect of or association with DHA and CVD clinical and intermediate outcomes. There is moderate strength of evidence of no effect of purified DHA supplementation on BP or LDL-c and low strength of evidence of no association between DHA intake and incident CHD (from observational studies).
- Marine oils, DPA
  ○ Overall, there is insufficient evidence regarding effect of or association between DPA (specifically) and most CVD clinical and intermediate outcomes. There is low strength of evidence of no association between DPA biomarker levels and risk of AFib.
- SDA
  ○ Overall, there is insufficient evidence regarding effect of or association between SDA (specifically) and CVD clinical and intermediate outcomes.
- ALA
  ○ There is moderate strength of evidence of no significant effect of ALA intake on BP, LDL-c, HDL-c, or Tg. There is low strength of evidence of no association between ALA intake or biomarker level and CHD or CHD death, AFib, and CHF, each based on observational studies. There is insufficient evidence regarding other outcomes.

### Key Question 1, Subquestions

1.1.1 What is the efficacy or association of n-3 FA in preventing CVD outcomes in people without known CVD (primary prevention )?
  - There was insufficient evidence for cardiac death, CHF death, ischemic stroke death, hemorrhagic stroke death, revascularization, acute coronary syndrome, angina pectoris, ventricular arrhythmia, incident hypertension, TC/HDL-c ratio, and LDL-c/HDL-c ratio.
  - There was insufficient RCT evidence and inconsistent observational evidence for CHD death, MI death, all-cause death, total MI, and SCD.
  - There was insufficient RCT evidence but observational evidence of no association for MACE, CVD death, total stroke death, incident CHD, total stroke, ischemic stroke, hemorrhagic stroke, AFib, and CHF.
  - There was strong RCT evidence for no effect for BP (systolic and diastolic), MAP (only 3 trials), LDL-c, and HDL-c.
  - There was strong RCT evidence for a significant protective effect for Tg.
1.1.2 What is the efficacy or association of n-3 FA in preventing CVD outcomes in people at high risk for CVD (primary prevention)?
  - There was insufficient evidence for CVD death, cardiac death, CHD death, MI death, CHF death, total stroke death, ischemic stroke death, hemorrhagic stroke death, incident CHD, revascularization, acute coronary syndrome, angina pectoris, total stroke, ischemic stroke, hemorrhagic stroke, SCD, AFib, ventricular arrhythmia, CHF, incident hypertension, and MAP.
  - There was inconsistent RCT evidence for total MI.
  - There was strong RCT evidence for no effect for MACE, all-cause death, BP (systolic and diastolic), LDL-c, HDL-c, TC/HDL-c ratio, and LDL-c/HDL-c ratio.
  - There was strong RCT evidence for a significant protective effect for Tg.
1.1.3 What is the efficacy or association of n-3 FA in preventing CVD outcomes in people with known CVD (secondary prevention)?
  - There was insufficient evidence for MI death, CHF death, total stroke death, ischemic stroke death, hemorrhagic stroke death, CHD, acute coronary syndrome, angina pectoris, ischemic stroke, hemorrhagic stroke, ventricular arrhythmia, incident hypertension, MAP, TC/HDL-c ratio, and LDL-c/HDL-c ratio.
  - There was inconsistent RCT evidence for CVD death and cardiac death. There was RCT evidence of no effect for MACE, CHD death, all-cause death, total MI, revascularization, total stroke, SCD, AFib, and CHF.
  - There was strong RCT evidence of no effect for BP (systolic and diastolic) and LDL-c.
  - There was strong RCT evidence of a protective effect for HDL-c and Tg.
1.2 What is the relative efficacy of different n-3 FA on CVD outcomes and risk factors?
  - There is low strength of evidence of no difference between EPA+DHA and its individual components.
  - There is low strength of evidence of greater efficacy of marine oils over ALA.
1.3 Can the CVD outcomes be ordered by strength of intervention effect of n-3 FA ?
  - Based on the summary effect sizes of meta-analyzed RCTs, marine oils had no significant effect on CVD outcomes. The order of effect sizes of CVD outcomes with sufficient data to allow meta-analysis, was MI (ES=0.88), CVD death (ES=0.92), MACE (ES=0.96), all-cause death (ES=0.97), total stroke (ES=0.98), and SCD (ES=1.04).

### Key Question 2

#### n-3 FA variables and modifiers

2.1 How does the efficacy or association of n-3 FA in preventing CVD outcomes and with CVD risk factors differ in subpopulations, including men, premenopausal women, postmenopausal women, and different age or race/ethnicity groups?
  - There was insufficient evidence to assess the efficacy or association of n-3 FA in preventing CVD outcomes and with CVD risk factors in subgroups based on race/ethnicity and whether women were pre- or postmenopausal.
  - 5 studies (mostly observational) found no significant differences in association based on age, with cutoffs for subgroups ranging between 60 and 70 years of age.
  - Two studies found no interaction with age as a continuous variable. One trial found a significant difference in favor of women, two observational studies found a significant difference in favor of men, and 9 studies (mix of RCT and observational) found no difference between men and women.
2.2 What are the effects of potential confounders or interacting factors—such as plasma lipids, body mass index, BP, diabetes, kidney disease, other nutrients or supplements, and drugs (e.g., statins, aspirin, diabetes drugs, hormone replacement therapy)?
  - There was insufficient evidence to assess the following potential confounders or interacting factors: beta-blocker use, baseline HDL-c, glargine use, nitrate use, digoxin use, diuretic use, eGFR, ACEi use, anticoagulant use, total cholesterol levels, or use of fish oil supplements.
  - There was inconsistent evidence for the following potential confounders or interacting factors: triglyceride levels, statin use, b-vitamin use, and baseline LDL-c.
  - There was evidence of no interactions with body mass index, hypertension status, diabetes status, and baseline TC/HDL-c ratio.
2.3 What is the efficacy or association of different ratios of n-3 FA components in dietary supplements or biomarkers on CVD outcomes and risk factors?
  - No study directly compared efficacy or association of different ratios of n-3 FA components on outcomes. Across studies, there were insufficient data to make these assessments.
2.4 How does the efficacy or association of n-3 FA on CVD outcomes and risk factors differ by ratios of different n-3 FA—DHA, EPA, and ALA, or other n-3 FA?
  - No study directly compared efficacy or association of different ratios of n-3 FA components on outcomes. Across studies, there were insufficient data to make these assessments.
2.5 How does the efficacy or association of n-3 FA on CVD outcomes and risk factors differ by source (e.g., fish and vs. seafood, common plant oils (e.g., soybean vs,, canola), fish oil supplements, fungal-algal supplements, flaxseed oil supplements)?
  - No study directly compared efficacy or association of different sources of n-3 FA on outcomes. Across studies, there were insufficient data to make these assessments.
2.6 How does the ratio of n-6 FA to n-3 FA intakes or biomarker concentrations affect the efficacy or association of n-3 FA on CVD outcomes and risk factors?
  - No trial or observational studies evaluated n-6 FA to n-3 FA intake concentrations and no differences across studies by this ratio was evident.
2.7 Is there a threshold or dose-response relationship between n-3 FA exposures and CVD outcomes and risk factors? Does the study type affect these relationships?
  - Among trials, for all clinical CVD outcomes there is insufficient evidence regarding a dose-response relationship within or between trials.
  - For BP, LDL-c, and HDL-c, trials do not find significant differences in effect by marine oil dose either within or between trials.
  - Trials comparing marine oil doses mostly found no significant difference between higher and lower dose marine oils. However, a possible pattern could be discerned such that higher doses of 3.4 or 4 g/d reduced Tg by at least 30 mg/dL more than lower doses of 1 to 2 g/d. Higher doses ≤3 g/d (1.7–3 g/d) yielded much smaller relative differences in Tg change compared to lower doses (0.7–2.25 g/d). By metaregression, each increase of EPA+DHA dose by 1 g/d was associated with a greater net change Tg of −5.9 mg/dL (95% CI −9.9 to−2.0; P=0.003); no inflection point was found above which the association plateaued.
  - Metaregressions of observational studies yielded the following conclusions:
    ○ For all-cause death, there may be a ceiling effect at about 0.2 g/d, such that increasing marine oil intake up to this level may be associated with lower all-cause death, but increasing intake above this level may not be associated with further decreased risk.
    ○ For total stroke, ischemic stroke, and CHF, at lower ranges of intake there were statistically significant associations between higher marine oil intake level and lower risk of outcome, in contrast to associations found at higher ranges of intake. However, the associations at lower and higher doses were not statistically significant from each other. For ischemic stroke, associations between higher doses and risk of stroke were stronger and statistically significant across lower doses than at higher doses (with thresholds between lower and higher doses from 0.1 and 0.4 g/d) and the differences in associations between lower and higher doses were statistically significant. Any dose inflection point that may exist is likely to be beyond the range of testable thresholds (i.e., >0.4 g/d). Similarly, for CHF significant associations were found at lower doses, in contrast to at higher doses, with thresholds ranging from 0.1 to 0.5 g/d, and the differences were statistically significant at most thresholds. Any dose inflection point that may exist is likely to be beyond the range of testable thresholds (i.e., >0.5 g/d).
    ○ For CVD death, CHD death, total CHD, and hemorrhagic stroke, there were no apparent differences in association between marine oil intake dose and outcome at lower or higher dose ranges.
    ○ For CHD death and CHD, there were no apparent differences in association between ALA intake dose and outcome at lower or higher dose ranges.
2.8 How does the duration of intervention or exposure influence the effect of n-3 FA on CVD outcomes and risk factors?
  - None of the meta-regressions found a significant interaction for follow-up time. No difference in effect was found within studies at different durations of intervention. Observational studies did not evaluate differences in duration of exposure.
2.9 What is the effect of baseline n-3 FA status (intake or biomarkers) on the efficacy of n-3 FA intake or supplementation on CVD outcomes and risk factors?
  - No study found a significant difference in subgroups based on baseline fish or n-3 FA intake.

### Key Question 3

#### Adverse events

3.1 What adverse effects are related to n-3 FA intake (in studies of CVD outcomes and risk factors)?
  - No serious or severe adverse events were related to n-3 FA intake (supplementation). Most reported adverse events were mild and gastrointestinal in nature; however, only 2 of 25 trials reported statistically significant differences in adverse events between n-3 FA supplements and placebo.
3.2 What adverse events are reported specifically among people with CVD or diabetes (in studies of CVD outcomes and risk factors)?
  - Among 10 trials of patients with CVD (9 with marine oil, 1 with total n-3 FA, 2 with ALA), either no adverse events or no significant difference between n-3 FA and placebo were reported.
  - A single study reported adverse events from a trial of people with diabetes, finding no significant differences in serious or nonserious adverse events between marine oil and placebo.