# References

1 Bang HO, Dyerberg J, Hjoorne N. (1976). The composition of food consumed by Greenland Eskimos. Acta medica Scandinavica.
2 Burdge GC, Calder PC. (2006). Dietary alphalinolenic acid and health-related outcomes: a metabolic perspective. Nutr Res Rev.
3 Balk E, Chung M, Lichtenstein A, et al. (2004). Effects of omega-3 fatty acids on cardiovascular risk factors and intermediate markers of cardiovascular disease. Evid Rep Technol Assess (Summ).
4 Wang C, Chung M, Lichtenstein A, et al. (2004). Effects of omega-3 fatty acids on cardiovascular disease. Evid Rep Technol Assess (Summ).
5 (2011). Report of the Joint FAO/WHO Expert Consultation on the Risks and Benefits of Fish Consumption Food and Agriculture Organization of the United Nations.
6 Institute of Medicine, Panel on Micronutrients. (2005). Dietary Reference Intakes for Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein and Amino Acids Panel on Macronutrients Panel on the Definition of Dietary Fiber, Subcommittee on Upper Reference Levels of Nutrients, Subcommittee on Interpretation and Uses of Dietary Reference Intakes, and the Standing Committee on the Scientific Evaluation of Dietary Reference Intakes, Food and Nutrition Board.
7 McGuire S. (2011). US Department of Agriculture and US Department of Health and Human Services, Dietary Guidelines for Americans, 2010. (2011). Adv Nutr.
8 Institute of Medicine. (2007). Nesheim MC, Yaktine AL, editors. Seafood Choices: Balancing Benefits and Risks.
9 Harika RK, Eilander A, Alssema M, et al. (2013). Intake of fatty acids in general populations worldwide does not meet dietary recommendations to prevent coronary heart disease: a systematic review of data from 40 countries. Ann Nutr Metab.
10 Balk EM, Horsley TA, Newberry SJ, et al. (2007). A collaborative effort to apply the evidence-based review process to the field of nutrition: challenges, benefits, and lessons learned. Am J Clin Nutr.
11 Chung M, Balk EM, Ip S, et al. (2010). Systematic review to support the development of nutrient reference intake values: challenges and solutions. Am J Clin Nutr.
12 Chung M, Balk EM, Ip S, et al. (2009). Reporting of Systematic Reviews of Micronutrients and Health: A Critical Appraisal: Nutrition Research Series.
13 Chung M, Balk EM, Ip S, et al. (2009). Reporting of systematic reviews of micronutrients and health: a critical appraisal. Am J Clin Nutr.
14 Chung M, Newberry SJ, Ansari MT, et al. (2012). Two methods provide similar signals for the need to update systematic reviews. J Clin Epidemiol.
15 Lichtenstein AH, Yetley EA, Lau J. (2008). Application of systematic review methodology to the field of nutrition. J Nutr.
16 Lichtenstein AH, Yetley EA, Lau J. (2009). Application of Systematic Review Methodology to the Field of Nutrition: Nutritional Research Series.
17 Moorthy D, Chung M, Lee J, et al. (2013). Concordance Between the Findings of Epidemiological Studies and Randomized Trials in Nutrition: An Empirical Evaluation and Citation Analysis: Nutritional Research Series.
18 Russell R, Chung M, Balk EM, et al. (2009). Opportunities and challenges in conducting systematic reviews to support the development of nutrient reference values: vitamin A as an example. Am J Clin Nutr.
19 Russell R, Chung M, Balk EM, et al. (2009). Issues and Challenges in Conducting Systematic Reviews to Support Development of Nutrient Reference Values: Workshop Summary: Nutrition Research Series.
20 Shekelle PG, Newberry SJ, Wu H, et al. (2011). Identifying Signals for Updating Systematic Reviews: A Comparison of Two Methods.
21 Trikalinos TA, Lee J, Moorthy D, et al. (2012). Effects of Eicosapentanoic Acid and Docosahexanoic Acid on Mortality Across Diverse Settings: Systematic Review and Meta-Analysis of Randomized Trials and Prospective Cohorts: Nutritional Research Series.
22 Trikalinos TA, Moorthy D, Chung M, et al. (2011). Comparison of Translational Patterns in Two Nutrient-Disease Associations: Nutritional Research Series.
23 Trikalinos TA, Moorthy D, Chung M, et al. (2012). Concordance of randomized and nonrandomized studies was unrelated to translational patterns of two nutrient-disease associations. J Clin Epidemiol.
24 Freedman LS, Commins JM, Moler JE, et al. (2014). Pooled results from 5 validation studies of dietary self-report instruments using recovery biomarkers for energy and protein intake. Am J Epidemiol.
25 Archer E, Hand GA, Blair SN. (2013). Validity of U.S. nutritional surveillance: National Health and Nutrition Examination Survey caloric energy intake data, 1971–2010. PloS One.
26 Schoeller DA, Thomas D, Archer E, et al. (2013). Self-report-based estimates of energy intake offer an inadequate basis for scientific conclusions. Am J Clin Nutr.
27 Hodson L, Skeaff CM, Fielding BA. (2008). Fatty acid composition of adipose tissue and blood in humans and its use as a biomarker of dietary intake. Progress in lipid research.
28 Serra-Majem L, Nissensohn M, Overby NC, et al. (2012). Dietary methods and biomarkers of omega 3 fatty acids: a systematic review. Br J Nutr.
29 Fekete K, Marosvolgyi T, Jakobik V, et al. (2009). Methods of assessment of n-3 long-chain polyunsaturated fatty acid status in humans: a systematic review. Am J Clin Nutr.
30 Khoueiry G, Abi Rafeh N, Sullivan E, et al. (2013). Do omega-3 polyunsaturated fatty acids reduce risk of sudden cardiac death and ventricular arrhythmias? A meta-analysis of randomized trials. Heart Lung.
31 Kotwal S, Jun M, Sullivan D, et al. (2012). Omega 3 Fatty acids and cardiovascular outcomes: systematic review and meta-analysis. Circ Cardiovasc Qual Outcomes.
32 Rizos EC, Ntzani EE, Bika E, et al. (2012). Association between omega-3 fatty acid supplementation and risk of major cardiovascular disease events: a systematic review and meta-analysis. JAMA.
33 Delgado-Lista J, Perez-Martinez P, Lopez-Miranda J, et al. (2012). Long chain omega-3 fatty acids and cardiovascular disease: a systematic review. Br J Nutr.
34 Kwak SM, Myung SK, Lee YJ, et al. (2012). Efficacy of omega-3 fatty acid supplements (eicosapentaenoic acid and docosahexaenoic acid) in the secondary prevention of cardiovascular disease: a meta-analysis of randomized, double-blind, placebo-controlled trials. Arch Intern Med.
35 Chen Q, Cheng LQ, Xiao TH, et al. (2011). Effects of omega-3 fatty acid for sudden cardiac death prevention in patients with cardiovascular disease: a contemporary meta-analysis of randomized, controlled trials. Cardiovascular drugs and therapy/sponsored by the International Society of Cardiovascular Pharmacotherapy.
36 Zhao YT, Chen Q, Sun YX, et al. (2009). Prevention of sudden cardiac death with omega-3 fatty acids in patients with coronary heart disease: a meta-analysis of randomized controlled trials. Ann Med.
37 Kramer BS, Wilentz J, Alexander D, et al. (2006). Getting it right: being smarter about clinical trials. PLoS Med.
38 Geleijnse JM, Giltay EJ, Grobbee DE, et al. (2002). Blood pressure response to fish oil supplementation: metaregression analysis of randomized trials. J Hypertens.
39 (2011). Methods guide for effectiveness and comparative effectiveness reviews.
40 Hill AB. (1965). The environment and disease: association or causation?. Proceedings of the Royal Society of Medicine.
41 Higgins JP, Altman DG, Gotzsche PC, et al. (2011). The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ (Clinical research ed).
42 Wells GASB, O’Connell D, Peterson J, Welch V, Losos M, Tugwell P. (2014). The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses.
43 Chung M, Balk EM, Brendel M, et al. (2009). Vitamin D and calcium: a systematic review of health outcomes. Evidence report/technology assessment.
44 Yu WW, Schmid CH, Lichtenstein AH, et al. (2013). Empirical evaluation of meta-analytic approaches for nutrient and health outcome dose-response data. Res Synth Methods.
45 Berkman ND, Lohr KN, Ansari MT, et al. (2014). Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol.
46 Liu M, Wallmon A, Wallin R, Saldeen T. Effects of stable fish oil and simvastatin on plasma lipoproteins in patients with hyperlipidemia. Nutrition research.
47 Dolecek TA. (1992). Epidemiological evidence of relationships between dietary polyunsaturated fatty acids and mortality in the multiple risk factor intervention trial. Proceedings of the Society for Experimental Biology and Medicine Society for Experimental Biology and Medicine (New York, NY).
48 Burr ML, Fehily AM, Gilbert JF, et al. (1989). Effects of changes in fat, fish, and fibre intakes on death and myocardial reinfarction: diet and reinfarction trial (DART). Lancet.
49 Natvig H, Borchgrevink CF, Dedichen J, et al. (1968). A controlled trial of the effect of linolenic acid on incidence of coronary heart disease. The Norwegian vegetable oil experiment of 1965–66. Scand J Clin Lab Invest Suppl.
50 Morris MC, Manson JE, Rosner B, et al. (1995). Fish consumption and cardiovascular disease in the physicians’ health study: a prospective study. Am J Epidemiol.
51 Sacks FM, Stone PH, Gibson CM, et al. (1995). Controlled trial of fish oil for regression of human coronary atherosclerosis. HARP Research Group. J Am Coll Cardiol.
52 Guallar E, Hennekens CH, Sacks FM, et al. (1995). A prospective study of plasma fish oil levels and incidence of myocardial infarction in U.S. male physicians. J Am Coll Cardiol.
53 Lungershausen YK, Abbey M, Nestel PJ, Howe PR. (1994). Reduction of blood pressure and plasma triglycerides by omega-3 fatty acids in treated hypertensives. J Hypertens.
54 Ascherio A, Rimm EB, Stampfer MJ. (1995). Dietary intake of marine n-3 fatty acids, fish intake, and the risk of coronary disease among men. N Engl J Med.
55 Sacks FM, Hebert P, Appel LJ, et al. (1994). Short report: the effect of fish oil on blood pressure and high-density lipoprotein-cholesterol levels in phase I of the Trials of Hypertension Prevention. J Hypertens.
56 Eritsland JAH, Gronseth K, Fjeld NB, Abdelnoor M. (1996). Effect of dietary supplementation with n-3 fatty acids on coronary artery bypass graft patency. The American journal of cardiology.
57 Pietinen P, Ascherio A, Korhonen P, et al. (1997). Intake of fatty acids and risk of coronary heart disease in a cohort of Finnish men. The Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Am J Epidemiol.
58 Sirtori CR, Paoletti R, Mancini M, et al. (1997). N-3 fatty acids do not lead to an increased diabetic risk in patients with hyperlipidemia and abnormal glucose tolerance. Italian Fish Oil Multicenter Study. Am J Clin Nutr.
59 Grimsgaard S, Bonaa KH, Hansen JB, Nordoy A. (1997). Highly purified eicosapentaenoic acid and docosahexaenoic acid in humans have similar triacylglycerol-lowering effects but divergent effects on serum fatty acids. Am J Clin Nutr.
60 Albert CM, Hennekens CH, O’Donnell CJ, et al. (1998). Fish consumption and risk of sudden cardiac death. JAMA.
61 Grimsgaard S, Bonaa KH, Hansen JB, Myhre ES. (1998). Effects of highly purified eicosapentaenoic acid and docosahexaenoic acid on hemodynamics in humans. Am J Clin Nutr.
62 von Schacky C, Angerer P, Kothny W, et al. (1999). The effect of dietary omega-3 fatty acids on coronary atherosclerosis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med.
63 Gruppo Italiano per lo Studio della Sopravvivenza nell’Infarto miocardico. (1999). Dietary supplementation with n-3 polyunsaturated fatty acids and vitamin E after myocardial infarction: results of the GISSI-Prevenzione trial. Lancet.
64 Ness AR, Whitley E, Burr ML, et al. (1999). The long-term effect of advice to eat more fish on blood pressure in men with coronary disease: results from the diet and reinfarction trial. J Hum Hypertens.
65 Iso H, Rexrode KM, Stampfer MJ, et al. (2001). Intake of fish and omega-3 fatty acids and risk of stroke in women. JAMA.
66 Vessby B, Uusitupa M, Hermansen K, et al. (2001). Substituting dietary saturated for monounsaturated fat impairs insulin sensitivity in healthy men and women: The KANWU Study. Diabetologia.
67 Nilsen DW, Albrektsen G, Landmark K, et al. (2001). Effects of a high-dose concentrate of n-3 fatty acids or corn oil introduced early after an acute myocardial infarction on serum triacylglycerol and HDL cholesterol. Am J Clin Nutr.
68 Yuan JM, Ross RK, Gao YT, Yu MC. (2001). Fish and shellfish consumption in relation to death from myocardial infarction among men in Shanghai, China. Am J Epidemiol.
69 Hu FB, Bronner L, Willett WC, et al. (2002). Fish and omega-3 fatty acid intake and risk of coronary heart disease in women. JAMA.
70 Marchioli R, Barzi F, Bomba E, et al. (2002). Early protection against sudden death by n-3 polyunsaturated fatty acids after myocardial infarction: time-course analysis of the results of the Gruppo Italiano per lo Studio della Sopravvivenza nell’Infarto Miocardico (GISSI)-Prevenzione. Circulation.
71 Ness AR, Hughes J, Elwood PC, et al. (2002). The long-term effect of dietary advice in men with coronary disease: follow-up of the Diet and Reinfarction trial (DART). Eur J Clin Nutr.
72 Nagata C, Takatsuka N, Shimizu H. (2002). Soy and fish oil intake and mortality in a Japanese community. Am J Epidemiol.
73 He K, Rimm EB, Merchant A, et al. (2002). Fish consumption and risk of stroke in men. JAMA.
74 Burr ML, Ashfield-Watt PA, Dunstan FD, et al. (2003). Lack of benefit of dietary advice to men with angina: results of a controlled trial. Eur J Clin Nutr.
75 Finnegan YE, Minihane AM, Leigh-Firbank EC, et al. (2003). Plant- and marine-derived n-3 polyunsaturated fatty acids have differential effects on fasting and postprandial blood lipid concentrations and on the susceptibility of LDL to oxidative modification in moderately hyperlipidemic subjects. Am J Clin Nutr.
76 Shidfar F, Keshavarz A, Jallali M, et al. (2003). Comparison of the effects of simultaneous administration of vitamin C and omega-3 fatty acids on lipoproteins, apo A-I, apo B, and malondialdehyde in hyperlipidemic patients. Int J Vitam Nutr Res.
77 Grundt H, Nilsen DW, Hetland O, Mansoor MA. (2004). Clinical outcome and atherothrombogenic risk profile after prolonged wash-out following long-term treatment with high doses of n-3 PUFAs in patients with an acute myocardial infarction. Clin Nutr.
78 Mozaffarian D, Ascherio A, Hu FB, et al. (2005). Interplay between different polyunsaturated fatty acids and risk of coronary heart disease in men. Circulation.
79 Frost L, Vestergaard P. (2005). n-3 Fatty acids consumed from fish and risk of atrial fibrillation or flutter: the Danish Diet, Cancer, and Health Study. Am J Clin Nutr.
80 Harrison RA, Sagara M, Rajpura A, et al. (2004). Can foods with added soya-protein or fish-oil reduce risk factors for coronary disease? A factorial randomised controlled trial. Nutrition, metabolism, and cardiovascular diseases: NMCD.
81 Raitt MH, Connor WE, Morris C, et al. (2005). Fish oil supplementation and risk of ventricular tachycardia and ventricular fibrillation in patients with implantable defibrillators: a randomized controlled trial. JAMA.
82 Leaf A, Albert CM, Josephson M, et al. (2005). Prevention of fatal arrhythmias in high-risk subjects by fish oil n-3 fatty acid intake. Circulation.
83 Albert CM, Oh K, Whang W, et al. (2005). Dietary alphalinolenic acid intake and risk of sudden cardiac death and coronary heart disease. Circulation.
84 Iso H, Kobayashi M, Ishihara J, et al. (2006). Intake of fish and n3 fatty acids and risk of coronary heart disease among Japanese: the Japan Public Health Center-Based (JPHC) Study Cohort I. Circulation.
85 Rasmussen BM, Vessby B, Uusitupa M, et al. (2006). Effects of dietary saturated, monounsaturated, and n-3 fatty acids on blood pressure in healthy subjects. Am J Clin Nutr.
86 Brouwer IA, Heeringa J, Geleijnse JM, et al. (2006). Intake of very long-chain n-3 fatty acids from fish and incidence of atrial fibrillation. The Rotterdam Study. Am Heart J.
87 Brouwer IA, Zock PL, Camm AJ, et al. (2006). Effect of fish oil on ventricular tachyarrhythmia and death in patients with implantable cardioverter defibrillators: the Study on Omega-3 Fatty Acids and Ventricular Arrhythmia (SOFA) randomized trial. JAMA.
88 Hjerkinn EM, Abdelnoor M, Breivik L, et al. (2006). Effect of diet or very long chain omega-3 fatty acids on progression of atherosclerosis, evaluated by carotid plaques, intima-media thickness and by pulse wave propagation in elderly men with hypercholesterolaemia. Eur J Cardiovasc Prev Rehabil.
89 Burr ML. (2007). Secondary prevention of CHD in UK men: the Diet and Reinfarction Trial and its sequel. Proc Nutr Soc.
90 Yokoyama M, Origasa H, Matsuzaki M, et al. (2007). Effects of eicosapentaenoic acid on major coronary events in hypercholesterolaemic patients (JELIS): a randomised open-label, blinded endpoint analysis. Lancet.
91 Davidson MH, Stein EA, Bays H, et al. (2007). Efficacy and tolerability of adding prescription omega-3 fatty acids 4 g/d to simvastatin 40 mg/d in hypertriglyceridemic patients: an 8-week, randomized, double-blind, placebo-controlled study. Clin Ther.
92 Marchioli R, Marfisi RM, Borrelli G, et al. (2007). Efficacy of n-3 polyunsaturated fatty acids according to clinical characteristics of patients with recent myocardial infarction: insights from the GISSI-Prevenzione trial. J Cardiovascular Med (Hagerstown).
93 Tanaka K, Ishikawa Y, Yokoyama M, et al. (2008). Reduction in the recurrence of stroke by eicosapentaenoic acid for hypercholesterolemic patients: subanalysis of the JELIS trial. Stroke; a journal of cerebral circulation.
94 Damsgaard CT, Frokiaer H, Andersen AD, Lauritzen L. (2008). Fish oil in combination with high or low intakes of linoleic acid lowers plasma triacylglycerols but does not affect other cardiovascular risk markers in healthy men. J Nutr.
95 Warensjo E, Sundstrom J, Vessby B, et al. (2008). Markers of dietary fat quality and fatty acid desaturation as predictors of total and cardiovascular mortality: a population-based prospective study. Am J Clin Nutr.
96 Tavazzi L, Maggioni AP, Marchioli R, et al. (2008). Effect of n-3 polyunsaturated fatty acids in patients with chronic heart failure (the GISSI-HF trial): a randomised, double-blind, placebo-controlled trial. Lancet.
97 Caslake MJ, Miles EA, Kofler BM, et al. (2008). Effect of sex and genotype on cardiovascular biomarker response to fish oils: the FINGEN Study. Am J Clin Nutr.
98 Yamagishi K, Iso H, Date C, et al. (2008). Fish, omega-3 polyunsaturated fatty acids, and mortality from cardiovascular diseases in a nationwide community-based cohort of Japanese men and women the JACC (Japan Collaborative Cohort Study for Evaluation of Cancer Risk) Study. J Am Coll Cardiol.
99 Holman RR, Paul S, Farmer A, Tucker L, Stratton IM, Neil HA. (2009). Atorvastatin in Factorial with Omega-3 EE90 Risk Reduction in Diabetes (AFORRD): a randomised controlled trial. Diabetologia.
100 Yamagishi K, Nettleton JA, Folsom AR. (2008). Plasma fatty acid composition and incident heart failure in middle-aged adults: the Atherosclerosis Risk in Communities (ARIC) Study. Am Heart J.
101 Virtanen JK, Mozaffarian D, Chiuve SE, Rimm EB. (2008). Fish consumption and risk of major chronic disease in men. Am J Clin Nutr.
102 Levitan EB, Wolk A, Mittleman MA. (2009). Fish consumption, marine omega-3 fatty acids, and incidence of heart failure: a population-based prospective study of middle-aged and elderly men. Eur Heart J.
103 Derosa G, Maffioli P, D’Angelo A. (2009). Effects of long chain omega-3 fatty acids on metalloproteinases and their inhibitors in combined dyslipidemia patients. Expert Opin Pharmacother.
104 Marchioli R, Levantesi G, Silletta MG. (2009). Effect of n-3 polyunsaturated fatty acids and rosuvastatin in patients with heart failure: results of the GISSI-HF trial. Expert Rev Cardiovasc Ther.
105 Ebrahimi M, Ghayour-Mobarhan M, Rezaiean S, et al. (2009). Omega-3 fatty acid supplements improve the cardiovascular risk profile of subjects with metabolic syndrome, including markers of inflammation and auto-immunity. Acta cardiologica.
106 Troseid M, Arnesen H, Hjerkinn EM, Seljeflot I. (2009). Serum levels of interleukin-18 are reduced by diet and n-3 fatty acid intervention in elderly high-risk men. Metabolism: clinical and experimental.
107 Olano-Martin E, Anil E, Caslake M. (2010). Contribution of apolipoprotein E genotype and docosahexaenoic acid to the LDL-cholesterol response to fish oil. Atherosclerosis.
108 Dijkstra SC, Brouwer IA, van Rooij FJ, et al. (2009). Intake of very long chain n-3 fatty acids from fish and the incidence of heart failure: the Rotterdam Study. Eur J Heart Failure.
109 Joensen AM, Schmidt EB, Dethlefsen C, et al. (2010). Dietary intake of total marine n-3 polyunsaturated fatty acids, eicosapentaenoic acid, docosahexaenoic acid and docosapentaenoic acid and the risk of acute coronary syndrome - a cohort study. Br J Nutr.
110 Virtanen JK, Mursu J, Voutilainen S, Tuomainen TP. (2009). Serum long-chain n-3 polyunsaturated fatty acids and risk of hospital diagnosis of atrial fibrillation in men. Circulation.
111 Berry JD, Prineas RJ, van Horn L, et al. (2010). Dietary fish intake and incident atrial fibrillation (from the Women’s Health Initiative). Am J Cardiol.
112 Levitan EB, Wolk A, Mittleman MA. (2010). Fatty fish, marine omega-3 fatty acids and incidence of heart failure. Eur J Clin Nutr.
113 de Goede J, Geleijnse JM, Boer JM, et al. (2010). Marine (n-3) fatty acids, fish consumption, and the 10-year risk of fatal and nonfatal coronary heart disease in a large population of Dutch adults with low fish intake. J Nutr.
114 Geleijnse JM, Giltay EJ, Schouten EG, et al. (2010). Effect of low doses of n-3 fatty acids on cardiovascular diseases in 4,837 post-myocardial infarction patients: design and baseline characteristics of the Alpha Omega Trial. Am Heart J.
115 Einvik K, Klemsdal TO, Sandvik L, Hjerkinn EM. (2010). A randomized clinical trial on n-3 polyunsaturated fatty acids supplementation and all-cause mortality in elderly men at high cardiovascular risk. Eur J Cardiovasc Prev Rehabil.
116 Maki KC, Dicklin MR, Davidson MH, et al. (2010). Baseline lipoprotein lipids and low-density lipoprotein cholesterol response to prescription omega-3 acid ethyl ester added to Simvastatin therapy. Am J Cardiol.
117 Ishikawa Y, Yokoyama M, Saito Y, et al. (2010). Preventive effects of eicosapentaenoic acid on coronary artery disease in patients with peripheral artery disease. Circ J.
118 Wang L, Manson JE, Forman JP, et al. (2010). Dietary fatty acids and the risk of hypertension in middle-aged and older women. Hypertension.
119 Kromhout D, Giltay EJ, Geleijnse JM. (2010). n-3 fatty acids and cardiovascular events after myocardial infarction. N Engl J Med.
120 Tierney AC, McMonagle J, Shaw DI, et al. (2011). Effects of dietary fat modification on insulin sensitivity and on other risk factors of the metabolic syndrome--LIPGENE: a European randomized dietary intervention study. Int J Obes (Lond).
121 Rauch B, Schiele R, Schneider S, et al. (2010). OMEGA, a randomized, placebo-controlled trial to test the effect of highly purified omega-3 fatty acids on top of modern guideline-adjusted therapy after myocardial infarction. Circulation.
122 Itakura H, Yokoyama M, Matsuzaki M, et al. (2011). Relationships between plasma fatty acid composition and coronary artery disease. J Atheroscler Thromb.
123 Galan P, Kesse-Guyot E, Czernichow S, et al. (2010). Effects of B vitamins and omega 3 fatty acids on cardiovascular diseases: a randomised placebo controlled trial. BMJ (Clinical research ed).
124 Xun P, Hou N, Daviglus M, et al. (2011). Fish oil, selenium and mercury in relation to incidence of hypertension: a 20-year follow-up study. J Intern Med.
125 Nodari S, Triggiani M, Campia U, et al. (2011). Effects of n-3 polyunsaturated fatty acids on left ventricular function and functional capacity in patients with dilated cardiomyopathy. J Am Coll Cardiol.
126 Woodward M, Tunstall-Pedoe H, Batty GD, et al. (2011). The prognostic value of adipose tissue fatty acids for incident cardiovascular disease: results from 3944 subjects in the Scottish Heart Health Extended Cohort Study. Eur Heart J.
127 de Goede J, Verschuren WM, Boer JM, et al. (2011). Alphalinolenic acid intake and 10-year incidence of coronary heart disease and stroke in 20,000 middle-aged men and women in the Netherlands. PloS One.
128 Carrepeiro MM, Rogero MM, Bertolami MC, et al. (2011). Effect of n-3 fatty acids and statins on oxidative stress in statin-treated hypercholestorelemic and normocholesterolemic women. Atherosclerosis.
129 Belin RJ, Greenland P, Martin L, et al. (2011). Fish intake and the risk of incident heart failure: the Women’s Health Initiative. Circ Heart Fail.
130 Wang L, Tsai M, Manson JE, et al. (2011). Erythrocyte fatty acid composition is associated with the risk of hypertension in middle-aged and older women. J Nutr.
131 Szabo de Edelenyi F, Vergnaud AC, Ahluwalia N, et al. (2012). Effect of B-vitamins and n-3 PUFA supplementation for 5 years on blood pressure in patients with CVD. Br J Nutr.
132 Mozaffarian D, Lemaitre RN, King IB, et al. (2011). Circulating long-chain omega-3 fatty acids and incidence of congestive heart failure in older adults: the cardiovascular health study: a cohort study. Ann Intern Med.
133 Nodari S, Triggiani M, Campia U, et al. (2011). n-3 polyunsaturated fatty acids in the prevention of atrial fibrillation recurrences after electrical cardioversion: a prospective, randomized study. Circulation.
134 Joensen AM, Overvad K, Dethlefsen C, et al. (2011). Marine n-3 polyunsaturated fatty acids in adipose tissue and the risk of acute coronary syndrome. Circulation.
135 Vedtofte MS, Jakobsen MU, Lauritzen L, Heitmann BL. (2011). Dietary alphalinolenic acid, linoleic acid, and n-3 long-chain PUFA and risk of ischemic heart disease. Am J Clin Nutr.
136 Sanders TA, Hall WL, Maniou Z. (2011). Effect of low doses of long-chain n-3 PUFAs on endothelial function and arterial stiffness: a randomized controlled trial. Am J Clin Nutr.
137 Strom M, Halldorsson TI, Mortensen EL, Torp-Pedersen C, Olsen SF. (2012). Fish, n-3 fatty acids, and cardiovascular diseases in women of reproductive age: a prospective study in a large national cohort. Hypertension.
138 Levitan EB, Wolk A, Hakansson N, Mittleman MA. (2012). Alphalinolenic acid, linoleic acid and heart failure in women. Br J Nutr.
139 Larsson SC, Virtamo J, Wolk A. (2012). Dietary fats and dietary cholesterol and risk of stroke in women. Atherosclerosis.
140 Wu JH, Lemaitre RN, King IB, et al. (2012). Association of plasma phospholipid long-chain omega-3 fatty acids with incident atrial fibrillation in older adults: the cardiovascular health study. Circulation.
141 Eussen SR, Geleijnse JM, Giltay EJ, et al. (2012). Effects of n-3 fatty acids on major cardiovascular events in statin users and non-users with a history of myocardial infarction. Eur Heart J.
142 Blacher J, Czernichow S, Paillard F, Ducimetiere P, Hercberg S, Galan P. (2013). Cardiovascular effects of B-vitamins and/or N-3 fatty acids: the SU.FOL.OM3 trial. Int J Cardiol.
143 de Goede J, Verschuren WM, Boer JM, Kromhout D, Geleijnse JM. (2012). Gender-specific associations of marine n-3 fatty acids and fish consumption with 10-year incidence of stroke. PloS One.
144 Gronroos NN, Chamberlain AM, Folsom AR, et al. (2012). Fish, fish-derived n-3 fatty acids, and risk of incident atrial fibrillation in the Atherosclerosis Risk in Communities (ARIC) study. PloS One.
145 De Goede J, Verschuren WM, Boer JM, et al. (2013). N-6 and n-3 fatty acid cholesteryl esters in relation to incident stroke in a Dutch adult population: a nested case-control study. Nutr Metab Cardiovasc Dis.
146 Bosch J, Gerstein HC, Dagenais G, et al. (2012). n-3 fatty acids and cardiovascular outcomes in patients with dysglycemia. N Engl J Med.
147 Carter JR, Schwartz CE, Yang H, Joyner MJ. (2012). Fish oil and neurovascular control in humans. Am J Physiol Heart Circ Physiol.
148 Lemaitre RN, Sitlani C, Song X, et al. (2012). Circulating and dietary alphalinolenic acid and incidence of congestive heart failure in older adults: the Cardiovascular Health Study. Am J Clin Nutr.
149 Khaw KT, Friesen MD, Riboli E, Luben R, Wareham N. (2012). Plasma phospholipid fatty acid concentration and incident coronary heart disease in men and women: the EPIC-Norfolk prospective study. PLoS Med.
150 Earnest CP, Kupper JS, Thompson AM, Guo W, Church T. (2012). Complementary effects of multivitamin and omega-3 fatty acid supplementation on indices of cardiovascular health in individuals with elevated homocysteine. Int J Vitam Nutr Res.
151 Ballantyne CM, Bays HE, Kastelein JJ, et al. (2012). Efficacy and safety of eicosapentaenoic acid ethyl ester (AMR101) therapy in statin-treated patients with persistent high triglycerides (from the ANCHOR study). Am J Cardiol.
152 Baxheinrich A, Stratmann B, Lee-Barkey YH, et al. (2012). Effects of a rapeseed oil-enriched hypoenergetic diet with a high content of alphalinolenic acid on body weight and cardiovascular risk profile in patients with the metabolic syndrome. Br J Nutr.
153 Wilk JB, Tsai MY, Hanson NQ, Gaziano JM, Djousse L. (2012). Plasma and dietary omega-3 fatty acids, fish intake, and heart failure risk in the Physicians’ Health Study. Am J Clin Nutr.
154 Hara M, Sakata Y, Nakatani D, et al. (2013). Low levels of serum n-3 polyunsaturated fatty acids are associated with worse heart failure-free survival in patients after acute myocardial infarction. Circ J.
155 Matsumoto C, Matthan NR, Wilk JB, et al. (2013). Erythrocyte stearidonic acid and other n-3 fatty acids and CHD in the Physicians’ Health Study. Br J Nutr.
156 Vecka M, Dusejovska M, Stankova B, et al. (2012). N-3 polyunsaturated fatty acids in the treatment of atherogenic dyslipidemia. Neuro Endocrinol Lett.
157 Macchia A, Grancelli H, Varini S, et al. (2013). Omega-3 fatty acids for the prevention of recurrent symptomatic atrial fibrillation: results of the FORWARD (Randomized Trial to Assess Efficacy of PUFA for the Maintenance of Sinus Rhythm in Persistent Atrial Fibrillation) trial. J Am Coll Cardiol.
158 Fretts AM, Mozaffarian D, Siscovick DS, et al. (2013). Associations of plasma phospholipid and dietary alphalinolenic acid with incident atrial fibrillation in older adults: the Cardiovascular Health Study. J Am Heart Assoc.
159 Mozaffarian D, Lemaitre RN, King IB, et al. (2013). Plasma phospholipid long-chain omega-3 fatty acids and total and cause-specific mortality in older adults: a cohort study. Ann Intern Med.
160 Roncaglioni MC, Tombesi M, Avanzini F, et al. (2013). n-3 fatty acids in patients with multiple cardiovascular risk factors. N Engl J Med.
161 Tatsuno I, Saito Y, Kudou K, Ootake J. (2013). Efficacy and safety of TAK-085 compared with eicosapentaenoic acid in Japanese subjects with hypertriglyceridemia undergoing lifestyle modification: the omega-3 fatty acids randomized double-blind (ORD) study. J Clin Lipidol.
162 Takata Y, Zhang X, Li H, et al. (2013). Fish intake and risks of total and cause-specific mortality in 2 population-based cohort studies of 134,296 men and women. Am J Epidemiol.
163 Aleksova A, Masson S, Maggioni AP, et al. (2013). n-3 polyunsaturated fatty acids and atrial fibrillation in patients with chronic heart failure: the GISSI-HF trial. Eur J Heart Failure.
164 Yamagishi KF, AR, Steffen LM. (2013). Plasma fatty acid composition and incident ischemic stroke in middle-aged adults: the Atherosclerosis Risk in Communities (ARIC) Study. Cerebrovascular diseases (Basel, Switzerland).
165 Rix TA, Joensen AM, Riahi S, et al. (2013). Marine n-3 fatty acids in adipose tissue and development of atrial fibrillation: a Danish cohort study. Heart (British Cardiac Society).
166 Maki KC, Orloff DG, Nicholls SJ, et al. (2013). A highly bioavailable omega-3 free fatty acid formulation improves the cardiovascular risk profile in high-risk, statin-treated patients with residual hypertriglyceridemia (the ESPRIT trial). Clin Ther.
167 Rodriguez-Leyva D, Weighell W, Edel A, et al. (2013). Potent antihypertensive action of dietary flaxseed in hypertensive patients. Hypertension.
168 Ninomiya T, Nagata M, Hata J, et al. (2013). Association between ratio of serum eicosapentaenoic acid to arachidonic acid and risk of cardiovascular disease: the Hisayama Study. Atherosclerosis.
169 Tatsuno I, Saito Y, Kudou K, Ootake J. (2013). Long-term safety and efficacy of TAK-085 in Japanese subjects with hypertriglyceridemia undergoing lifestyle modification: the omega-3 fatty acids randomized long-term (ORL) study. J Clin Lipidol.
170 Koh AS, Pan A, Wang R, et al. (2015). The association between dietary omega-3 fatty acids and cardiovascular death: the Singapore Chinese Health Study. Eur J Prev Cardiol.
171 de Oliveira Otto MC, Wu JH, Baylin A, et al. (2013). Circulating and dietary omega-3 and omega-6 polyunsaturated fatty acids and incidence of CVD in the Multi-Ethnic Study of Atherosclerosis. J Am Heart Assoc.
172 Amiano P, Machon M, Dorronsoro M, et al. (2014). Intake of total omega-3 fatty acids, eicosapentaenoic acid and docosahexaenoic acid and risk of coronary heart disease in the Spanish EPIC cohort study. Nutr Metab Cardiovasc Dis.
173 Grieger JA, Miller MD, Cobiac L. (2014). Investigation of the effects of a high fish diet on inflammatory cytokines, blood pressure, and lipids in healthy older Australians. Food Nutr Res.
174 Vazquez C, Botella-Carretero JI, Corella D, et al. (2014). White fish reduces cardiovascular risk factors in patients with metabolic syndrome: the WISH-CARE study, a multicenter randomized clinical trial. Nutr Metab Cardiovasc Dis.
175 Miyagawa N, Miura K, Okuda N, et al. (2014). Long-chain n-3 polyunsaturated fatty acids intake and cardiovascular disease mortality risk in Japanese: a 24-year follow-up of NIPPON DATA80. Atherosclerosis.
176 Bell GA, Kantor ED, Lampe JW, et al. (2014). Intake of long-chain omega-3 fatty acids from diet and supplements in relation to mortality. Am J Epidemiol.
177 Kastelein JJ, Maki KC, Susekov A, et al. (2014). Omega-3 free fatty acids for the treatment of severe hypertriglyceridemia: the EpanoVa fOr Lowering Very high triglyceridEs (EVOLVE) trial. J Clin Lipidol.
178 Kuhnt K, Fuhrmann C, Kohler M, et al. (2014). Dietary echium oil increases long-chain n-3 PUFAs, including docosapentaenoic acid, in blood fractions and alters biochemical markers for cardiovascular disease independently of age, sex, and metabolic syndrome. J Nutr.
179 Soares TS, Piovesan CH, Gustavo Ada S, et al. (2014). Alimentary habits, physical activity, and Framingham global risk score in metabolic syndrome. Arq Bras Cardiol.
180 Jones PJ, Senanayake VK, Pu S, et al. (2014). DHA-enriched high-oleic acid canola oil improves lipid profile and lowers predicted cardiovascular disease risk in the canola oil multicenter randomized controlled trial. Am J Clin Nutr.
181 Vedtofte MS, Jakobsen MU, Lauritzen L, et al. (2014). Association between the intake of alphalinolenic acid and the risk of CHD. Br J Nutr.
182 Zeng FF, Sun LL, Liu YH, et al. (2014). Higher erythrocyte n-3 PUFAs are associated with decreased blood pressure in middle-aged and elderly Chinese adults. J Nutr.
183 Hellstrand S, Ericson U, Gullberg B, et al. (2014). Genetic variation in FADS1 has little effect on the association between dietary PUFA intake and cardiovascular disease. J Nutr.
184 Ras RT, Demonty I, Zebregs YE, et al. (2014). Low doses of eicosapentaenoic acid and docosahexaenoic acid from fish oil dose-dependently decrease serum triglyceride concentrations in the presence of plant sterols in hypercholesterolemic men and women. J Nutr.
185 Oh PC, Koh KK, Sakuma I, et al. (2014). Omega-3 fatty acid therapy dose-dependently and significantly decreased triglycerides and improved flow-mediated dilation, however, did not significantly improve insulin sensitivity in patients with hypertriglyceridemia. Int J Cardiol.
186 Fretts AM, Mozaffarian D, Siscovick DS, et al. (2014). Plasma phospholipid and dietary alphalinolenic acid, mortality, CHD and stroke: the Cardiovascular Health Study. Br J Nutr.
187 Shaikh NA, Yantha J, Shaikh S, et al. (2014). Efficacy of a unique omega-3 formulation on the correction of nutritional deficiency and its effects on cardiovascular disease risk factors in a randomized controlled VASCAZEN((R)) REVEAL Trial. Molecular and cellular biochemistry.
188 Pieters DJ, Mensink RP. (2015). Effects of stearidonic acid on serum triacylglycerol concentrations in overweight and obese subjects: a randomized controlled trial. Eur J Clin Nutr.
189 Tardivo AP, Nahas-Neto J, Orsatti CL, et al. (2015). Effects of omega-3 on metabolic markers in postmenopausal women with metabolic syndrome. Climacteric.
190 Pase MP, Grima N, Cockerell R, et al. (2015). The effects of long-chain omega-3 fish oils and multivitamins on cognitive and cardiovascular function: a randomized, controlled clinical trial. J Am Coll Nutr.
191 Bergkvist C, Berglund M, Glynn A, et al. (2015). Dietary exposure to polychlorinated biphenyls and risk of myocardial infarction - a population-based prospective cohort study. Int J Cardiol.
192 Edel AL, Rodriguez-Leyva D, Maddaford TG, et al. (2015). Dietary flaxseed independently lowers circulating cholesterol and lowers it beyond the effects of cholesterol-lowering medications alone in patients with peripheral artery disease. J Nutr.
193 Kromhout D, Geleijnse JM, de Goede J, et al. (2011). n-3 fatty acids, ventricular arrhythmia-related events, and fatal myocardial infarction in postmyocardial infarction patients with diabetes. Diabetes care.
194 Oh R. (2005). Practical applications of fish oil (Omega-3 fatty acids) in primary care. J Am Board Fam Pract.
195 Brinton EA, Ballantyne CM, Bays HE, et al. (2013). Effects of icosapent ethyl on lipid and inflammatory parameters in patients with diabetes mellitus-2, residual elevated triglycerides (200–500 mg/dL), and on statin therapy at LDL-C goal: the ANCHOR study. Cardiovasc Diabetol.
196 Mozaffarian D, Wu JH. (2011). Omega-3 fatty acids and cardiovascular disease: effects on risk factors, molecular pathways, and clinical events. J Am Coll Cardiol.
197 Yakoot M. (2012). Vitamin e and omega-3: what to believe: observational studies or randomized controlled trials?. Heart views.