# Introduction

## Background

Since the first ecological study published in the late 1970s noted a relatively low cardiovascular (CV) mortality in a Greenland Eskimo population with high fish consumption,1 there have been hundreds of observational studies and clinical trials conducted to evaluate the effect of omega–3 fatty acids (n-3 FA) on CV disease (CVD) and its risk factors and intermediate markers. The n-3 FA (including alphalinolenic acid [ALA], stearidonic acid [SDA], eicosapentaenoic acid [EPA], docosapentaenoic acid [DPA], and docosahexaenoic acid [DHA]) are a group of long-chain and very-long-chain polyunsaturated fatty acids (PUFA) that are substrates for the synthesis of eicosanoids and are important components of cell membranes that impact fluidity. Eicosanoids (including prostaglandins, thromboxanes, and leukotrienes) have wide ranges of physiologic effects and play a key role in inflammation regulation. The metabolic pathway of n-3 FA is shown in Figure 1. ALA is the shortest n-3 FA from which all other n-3 FA, if not ingested preformed, are metabolically derived. ALA is an essential nutrient; it cannot be made by the human body and must come from the diet. SDA can be formed from ALA via Δ6 desaturase, the rate-limiting enzyme in the pathway. If SDA enters the metabolic pathway preformed, between 15 and 30 percent can be elongated and saturated to EPA. EPA can be converted to DPA and vice versa. However, the elongation and desaturation of ALA to EPA and DHA is inefficient. Based on stable-isotope tracer studies the estimated conversion rates are broad, ranging from 0.2 to 5 percent.2 Major dietary sources of ALA include soybean and canola oils, some nuts, and flaxseed. The major dietary sources of EPA and DHA are fish, other marine life, and marine-derived supplements. There is no naturally occurring source of SDA that, per serving, provides amounts of n-3 FA approaching levels (of EPA and DHA) present in oily fish. Naturally occurring sources of SDA—hemp and echium seed oils—are not consumed by the general population. In the future, though, SDA may be present in genetically modified soybeans.

Figure 1 Metabolic pathway of omega-3 fatty acids

Abbreviations: ALA = alphalinolenic acid, SDA = stearidonic acid, EPA = eicosapentaenoic acid, DPA = docosapentaenoic acid, DHA = docosahexaenoic acid, n-3 = omega-3 fatty acids

This figure demonstrates the metabolic pathway of omega-3 fatty acids. ALA is the simplest omega-3 fatty acid from which all other omega-3 fatty acids are derived, including: SDA, EPA, DPA, and DHA, omega-6 fatty acid. The background text of the introduction describes this pathway in detail.

Since the publication of the original Agency for Healthcare and Research Quality (AHRQ) n-3 FA systematic reviews in 2004^3, 4^ the topic of n-3 FA and CVD has remained controversial and dynamic. This topic has been evaluated by several expert panels that were considering whether recommendations or reference values for intakes of EPA and DHA were warranted, either through naturally occurring sources of n-3 FA (e.g., fish consumption) and/or through the use of dietary supplements and fortified foods.5–8

In 2002, the Institute of Medicine (IOM) considered the evidence inadequate to establish an estimated average requirement for n-3 FA.6 Thus the IOM established only adequate intake values for ALA, based on current population ALA intake and an apparent absence of deficiency symptoms. For healthy adults, the adequate intake values for ALA are 1.1 g/d for females and 1.6 g/d for males.6 After evaluating evidence linking the very-long-chain n-3 FA—EPA and DHA—to coronary heart disease (CHD, also known as coronary artery disease) and stroke, the IOM panel suggested that n-3 FA may provide beneficial health effects with respect to CHD and stroke; the acceptable macronutrient distribution range (a range of intakes that is associated with reduced risk of chronic diseases while providing adequate intakes of essential nutrients) for ALA was set at 0.6 to 1.2 percent of energy (roughly equivalent to 1 to 3 g/d), where 10 percent of this range can be consumed as EPA and/or DHA.6 For comparison, the mean intake of ALA in the United States has been estimated at 0.6 percent of energy intake (standard deviation 1.0%),9 equivalent to approximately 1.4 g/d. This intake level, is fairly consistent across developed countries (0.3–1.0% of energy). However, estimated EPA and DHA intake in the United States are only 0.05 g/d and 0.08 g/d, respectively. In contrast, mean intake in South Korea is 0.4 g/d of EPA and DHA, combined.9

SDA and DPA have only infrequently been analyzed in regards to their association with CVD. Three other expert reports evaluated the potential health benefits of fish/seafood consumption.5, 7, 8 Based primarily on the availability of observational study data, these panels consistently suggested that regular consumption of fish and seafood is associated with lower risk of CHD and cardiac death. These recommendations were based primarily on assumptions of benefits from EPA and DHA and their content in fish and seafood.

However, determination of n-3 FA intake is problematic, both for population recommendations and in regards to research. In practice, all nutrients are quantified using a nutrient database, e.g., the U.S. Department of Agriculture National Nutrient Database for Standard Reference (http://ndb.nal.usda.gov/). The quantity of a nutrient is then estimated by the standard amount of nutrients in foods that are indexed in the nutrient database multiplied by the amount and frequency of the food consumption. However, n-3 FA in foods are not well estimated in the nutrient database and questionnaires commonly do not ask about cooking oils or dressings and may not ask about supplements (so that n-3 FA intake is estimated only from fish consumption); therefore quantification of n-3 FA intake from food frequency questionnaires is poor. Furthermore, some questionnaire do not include portion size, so further estimation or extrapolation of intake is required.

There have been secular trends in the prevention and treatment of CVD over the past several decades, particularly since the 2004 AHRQ reports on n-3 FA and CVD. These trends may have had an important impact on the potential effect or association between n-3 FA intake and CVD outcomes. Important among these trends are the lower rates of cardiac and cerebrovascular disease, concomitant with higher rates of treatment and control of dyslipidemia and hypertension. For at least the past 20 years American adults are increasingly likely to be treated with statins, antihypertensives, and low-dose aspirin. All of these pharmacologic interventions act on metabolic and biochemical pathways that n-3 FA also impact and this confounding may impact the purported CV benefits of n-3 FA, including lipid metabolism, blood pressure (BP) and vascular homeostasis, and inflammatory and coagulation pathways. These treatment trends may have contributed to the lower population-level CV benefit of higher n-3 FA intake because the underlying risk of CVD is now lower, hence, diminishing the potential impact of n-3 FA intake. Furthermore, diagnostic criteria for CVD events (e.g., myocardial infarction) and CV risk factors (e.g., metabolic syndrome) have been refined over time which may make older studies less applicable in terms of their outcomes and populations.

## Scope and Key Questions

### Scope of the Review

The National Institutes of Health’s Office of Dietary Supplements (ODS) has a long history of commissioning AHRQ-based systematic reviews and research methodology reports for nutrition-related topics (http://ods.od.nih.gov/Research/Evidence-Based_Review_Program.aspx). n-3 FA and their potential relationship to a broad range of health outcomes formed the basis for nine of these systematic reviews published between 2004 and 2006 and also served as examples for several methodological reports.10–23

There are ongoing concerns in the scientific community regarding systematic biases and random errors in the determination of intakes of n-3 FA from dietary and supplement sources using currently available assessment tools. The limitations of the current methods have been discussed elsewhere.24–26 To date, no alternate methods are available. Until “error-free” or “bias-free” methodologies are developed, it is crucial to evaluate the available data with these methodological quality and limitations in mind. Nutrient biomarkers can provide an objective measure of dietary status.27 However, the correspondence between intake and biomarker concentration not only reflects recent intake but subsequent metabolism (e.g., elongation, desaturation, metabolism to bioactive compounds). Current biomarkers used to estimate n-3 FA intake include ALA, EPA, DHA, and, less frequently, SDA and DPA, measured in adipose tissue, erythrocytes, plasma, or plasma phospholipids.27–29 Adipose tissue FA are thought to reflect long-term intake, erythrocyte FA are thought to reflect the previous 120 day intake, and plasma FA are thought to reflect more immediate intake.28

Several recent systematic reviews of randomized controlled trials (RCTs) in individuals with diagnosed CVD or at high risk of CVD have suggested mixed results as to whether there are benefits of very-long-chain PUFA (EPA and DHA) for reducing the risk of adverse CV outcomes.21, 30–36 Reasons for the apparent inconsistent scientific conclusions among several of the expert panels and the more recent systematic reviews are varied but may relate, in part, to whether the n-3 FA exposures were from fish (or other marine) or plant sources, or from dietary supplements. The expert reviews also vary as to whether they relied primarily on observational studies or RCTs.21, 30–36 Studies of different designs each have their own strengths and weakness that may result in differences in conclusions. For example, observational studies based on self-reported dietary assessments (e.g., food frequency questionnaires) may inaccurately estimate n-3 FA intake; RCTs of specific fish or other n-3 FA-rich food may impose an artificial dietary pattern that might not be applicable to the general population; RCTs of supplements might not fully account for differences in background n-3 FA intake; studies using either study design may have subtle differences in eligibility criteria, e.g., length of followup duration, or inclusion of ALA, EPA and DHA or only EPA and DHA, that significantly impacted the final conclusions. Since there are limitations to different study designs and ways of assessing associations, it is of interest to systematically compare results across different study types (e.g., interventional vs. prospective cohort studies) and different ways of evaluating exposures, and to account for differences in background n-3 FA intake. Also of interest is a systematic evaluation of possible reasons for inconsistencies between observational and RCT findings,37 in particular a tabulation of causality-related study features.

The purpose of the current systematic review is twofold: 1) to update earlier reviews of the state-of-the science on the topic of the effects of n-3 FA on CVD,4 and selected CVD risk factors and intermediate markers of CVD,3 and 2) to use this new review to collect additional information that would enhance the usefulness of this report for policy and clinical applications. The primary target audience for this report is clinical and nutrition researchers and policymakers, including ODS and panels revising dietary intake recommendations. The 2004 reviews screened about 7,500 abstracts and retrieved and screened 768 full text articles for potentially relevant human data. For CVD outcomes, 11 RCTs and one prospective cohort study reported outcomes in individuals with diagnosed CVD, and 22 prospective cohort studies and one RCT reported data on the general population. The report on intermediate CVD outcomes included the 25 largest RCTs with lipid outcomes, an existing systematic review of BP,38 and six RCTs of BP in people with diabetes (who had been excluded from the existing systematic review). This review updates the previous review for the outcomes included and also expands the scope to include additional CVD outcomes (peripheral vascular disease, congestive heart failure (CHF), and arrhythmias); it updates BP and plasma lipid outcomes from, and adds incident hypertension to, the 2004 review of CVD risk factors and intermediate markers of CVD3; it adds associations between biomarkers of n-3 FA intake and outcomes.

### Key Questions

The Key Questions address both issues of efficacy (i.e., causal relationships from trials) as well as associations (i.e., prospective observational cohort study associations of n-3 FA intake and/or biomarkers with long-term outcomes; biomarker associations reported in RCTs). Compared with the Key Questions from the 2004 reports, the current Key Questions expand the scope of the review to include additional CV outcomes (BP, CHF, and arrhythmias), focus on the intermediate outcomes plasma lipids and BP, adds the intermediate outcome hypertension, and include associations between biomarkers of intake and outcomes.

1. What is the efficacy or association of n-3 FA (EPA, DHA, EPA+DHA, DPA, SDA, ALA, or total n-3 FA) exposures in reducing CVD outcomes (incident CVD events including all-cause death, CVD death, nonfatal CVD events, new diagnosis of CVD, peripheral vascular disease, CHF, major arrhythmias, and hypertension diagnosis) and specific CVD risk factors (BP, key plasma lipids)?
  - What is the efficacy or association of n-3 FA in preventing CVD outcomes in people
    ○ Without known CVD (primary prevention)
    ○ At high risk for CVD (primary prevention), and
    ○ With known CVD (secondary prevention)?
  - What is the relative efficacy of different n-3 FA on CVD outcomes and risk factors?
  - Can the CVD outcomes be ordered by strength of intervention effect of n-3 FA?
2. n-3 FA variables and modifiers:
  - How does the efficacy or association of n-3 FA in preventing CVD outcomes and with CVD risk factors differ in subpopulations, including men, premenopausal women, postmenopausal women, and different age or race/ethnicity groups?
  - What are the effects of potential confounders or interacting factors—such as plasma lipids, body mass index, BP, diabetes, kidney disease, other nutrients or supplements, and drugs (e.g., statins, aspirin, diabetes drugs, hormone replacement therapy)?
  - What is the efficacy or association of different ratios of n-3 FA components in dietary supplements or biomarkers, on CVD outcomes and risk factors?
  - How does the efficacy or association of n-3 FA on CVD outcomes and risk factors differ by ratios of different n-3 FA—DHA, EPA, and ALA, or other n-3 FA?
  - How does the efficacy or association of n-3 FA on CVD outcomes and risk factors differ by source (e.g., fish and seafood, common plant oils (e.g., soybean, canola), fish oil supplements, fungal-algal supplements, flaxseed oil supplements)?
  - How does the ratio of n-6 FA to n-3 FA intakes or biomarker concentrations affect the efficacy or association of n-3 FA on CVD outcomes and risk factors?
  - Is there a threshold or dose-response relationship between n-3 FA exposures and CVD outcomes and risk factors? Does the study type affect these relationships?
  - How does the duration of intervention or exposure influence the effect of n-3 FA on CVD outcomes and risk factors?
  - What is the effect of baseline n-3 FA status (intake or biomarkers) on the efficacy of n-3 FA intake or supplementation on CVD outcomes and risk factors?
3. Adverse events:
  - What adverse effects are related to n-3 FA intake or biomarker concentrations (in studies of CVD outcomes and risk factors)?
  - What adverse events are reported specifically among people with CVD or diabetes (in studies of CVD outcomes and risk factors)?

## Analytic Framework

To guide the assessment of studies that examine the association between n-3 FA intake and CV outcomes, the analytic framework maps the specific linkages associating the populations of interest, the exposures, modifying factors, and outcomes of interest (Figure 2). The framework graphically presents the key components of well-formulated study questions:

1. Who are the participants (i.e., what is the population and setting of interest, including the diseases or conditions of interest)?
2. What are the interventions?
3. What are the outcomes of interest (intermediate and health outcomes)?
4. What study designs are of value?

Figure 2 Analytic framework for omega–3 fatty acid exposure and cardiovascular disease

This framework concerns the effect of n-3 FA exposure (as a supplement or from food sources) on CVD and CVD risk factors. Populations of interest are noted in the top rectangle, exposure in the oval, outcomes in the rounded rectangles, and effect modifiers in the hexagon.

* Specifically, cardiovascular medications, statins, antihypertensives, diabetes medications, hormone replacement regimens.

† Systolic blood pressure, diastolic blood pressure, mean arterial pressure, high density lipoprotein cholesterol (HDL-c), low density lipoprotein cholesterol (LDL-c), total/HDL-c ratio, LDL-c/HDL-c ratio, triglycerides.

‡ Many other intermediate outcomes are likely in the causal pathway between n-3 FA intake and cardiovascular outcome, but only blood pressure and plasma lipids were included in the review.

Abbreviations: ALA = alphalinolenic acid, CHD = coronary heart disease, CHF = congestive heart failure, CKD = nondialysis-dependent chronic kidney disease, CMS = cardiometabolic syndrome, CVA = cerebrovascular accident (stroke), CVD = cardiovascular disease, DHA = docosahexaenoic acid, DM = diabetes mellitus, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, FA = fatty acid, HDL-c = high density lipoprotein cholesterol, HTN = hypertension, LDL-c = low density lipoprotein cholesterol, MI = myocardial infarction, n-3 = omega–3, n-6 = omega–6, PCI = percutaneous coronary intervention, SDA = stearidonic acid.

The analytic framework summarizes the key questions within the context of the PICO. Overall, the figure articulates the effect of omega-3 fatty acid consumption on cardiovascular outcomes. The target populations of interest include healthy adults with no known cardiovascular disease, adults at high risk for cardiovascular disease, including those with diabetes, cardiometabolic syndrome, hypertension, dyslipidemia, and non-dialysis-dependent chronic kidney disease, and adults with known cardiovascular disease. Omega-3 fatty acid consumption (including SDA, DHA, EPA, and ALA, of various sources, quantities, and durations of exposure) alters biomarkers of omega-3 fatty acid intake (including blood cell membrane fatty acids, plasma or phospholipid fatty acids, and adipose tissue fatty acids). Omega-3 fatty acid intake and biomarkers may affect cardiovascular intermediate outcomes, including blood pressure, lipids, and other factors not included in the current review. Both through the intermediate outcomes and directly, omega-3 fatty acid intake and biomarkers may be associated with clinical cardiovascular outcomes, including all-cause and cardiovascular death, myocardial infarction and other coronary artery disease events, congestive heart failure and other cardiac events, stroke and other cerebrovascular events, new vascular diagnoses including cardiac, cerebrovascular, and peripheral diseases, new ventricular and supraventricular arrhythmias, and cardiovascular disease-related procedures, such as percutaneous coronary interventions and amputation. All of these associations may be modified by different demographics, cardiovascular disease risk factors, omega-3 fatty acid type and source, omega-6 to omega-3 fatty acid ratios, background omega-3 fatty acid intake, other nutrients, exposure duration, and medications, specifically cardiovascular medications, statins, antihypertensives, diabetes medications, and hormone replacement. Omega-3 fatty acid intake can also be associated with adverse events.

Specifically, this analytic framework depicts the chain of logic that evidence must support to link the intervention (exposure to n-3 FA) to improved health outcomes.