# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Philip Calder, Ph.D., R.Nutr.
  University of Southampton
  Southampton, United Kingdom
- William R. Harlan, M.D.^*^
  Associate Director for Disease Prevention (Ret)
  National Institutes of Health
  Chevy Chase, MD
- Van S. Hubbard, M.D., Ph.D.
  Current:
  Rear Admiral, U.S. Public Health Service (Ret)
  At time of review:
  National Institutes of Health
  Director
  Division of Nutrition Research Coordination
  Associate Director for Nutritional Sciences
  National Institute of Diabetes and Digestive and Kidney Diseases
  Washington, DC
- Charlotte Pratt, Ph.D., R.D.
  National Institutes of Health
  National Heart, Lung and Blood Institute
  Washington, DC
- Lu Wang, M.D., Ph.D.^*^
  Harvard Medical School
  Brigham and Women’s Hospital
  Boston, MA

* Provided input on Draft Report.