# Discussion

## Overall Summary of Key Findings

In this systematic review we identified 61 eligible randomized controlled trials (RCT)s (in 82 publications) and 37 eligible prospective longitudinal and nested case-control studies (in 65 publications) for inclusion based on prespecified eligibility criteria. Most of the 19 RCTs that evaluated the effects of marine oil supplements (eicosapentaenoic acid [EPA] + docosahexaenoic acid [DHA]) compared with placebo on clinical cardiovascular disease (CVD) outcomes in populations at risk for CVD or with CVD, while most of the observational studies examined the associations between intake of various individual omega-3 fatty acids (n-3 FA) and in combination with each other in relationship to long-term CVD events in generally healthy populations. The RCTs of intermediate CVD outcomes (blood pressure [BP] and lipids) were conducted in all three populations of interest (generally healthy, at risk for CVD—primarily due to dyslipidemia, or with CVD). Only a single observational study evaluated BP; none evaluated lipids.

The main findings of the studies, regarding effect or association of higher n-3 FA intake or biomarker level and outcomes are summarized in the following tables. Table 54 includes analyses of n-3 FA and outcome pairs for which there is evidence to support an effect or association of higher n-3 FA intake and risk of a CVD outcome or on a CV risk factor. These include high strength of evidence that higher marine oil intake statistically significantly raises high density lipoprotein cholesterol (HDL-c), lowers triglycerides (Tg) concentration and Total:HDL-c ratio, but also raises low density lipoprotein cholesterol (LDL-c). There is low strength of evidence that higher marine oil intake is associated with lower risk of ischemic stroke.

Table 54 Main findings of high, moderate, or low strength of evidence of significant effects or associations between omega-3 fatty acids and outcomes

There is high strength of evidence for the following effects or associations of higher n-3 FA intake or biomarker levels and lower CVD risks or events:; - Marine oil^*^ supplementation (or increased intake) and an increase in HDL-c; ○ RCTs (of mostly supplements); ○ Summary net change in HDL-c: 0.9 mg/dL (95% CI 0.2, 1.6); - Marine oil^*^ supplementation (or increased intake) and a decrease in Tg; ○ RCTs (of mostly supplements); ○ Summary net change in Tg: −24 mg/dL (95% CI −31, −18); - Marine oil^*^ supplementation (or increased intake) and a decrease in total cholesterol to HDL-c ratio; ○ RCTs (of mostly supplements); ○ Summary net change in Total:HDL-c ratio: −0.17 (95% CI −0.26, −0.09)
There is high strength of evidence for the following effects or associations of higher n-3 FA intake or biomarker levels and higher CVD risk:; - Marine oil^*^ supplementation (or increased intake) and an increase in LDL-c; ○ RCTs (of mostly supplements); ○ Summary net change in LDL-c: 2.0 mg/dL (95% CI 0.4, 3.6)
There is low strength of evidence for the following effects or associations of higher n-3 FA intake and lower CVD risks or events:; - Marine oil^*^ higher dietary intake and a lower risk of ischemic stroke; ○ Observational studies (of total dietary intake), significant by metaregression: 0.51 (95% CI 0.29, 0.89) per g/d

* Statements about “marine oil” are based on all evidence of analyses of EPA+DHA+DPA, EPA+DHA, EPA, DHA, and DPA as supplements (e.g., fish oil) or as components of dietary intake (e.g., from fatty fish).

Abbreviations: CHD = coronary heart disease (also known as coronary artery disease), CHF = congestive heart failure, CI = confidence interval, CVD = cardiovascular disease, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, HR = hazard ratio, LDL-c = low density lipoprotein cholesterol, n-3 FA = omega-3 fatty acids, RCT = randomized controlled trial, Tg = triglycerides.

Table 55 includes analyses of n-3 FA and outcome pairs for which there is evidence supporting no effect or association of n-3 FA intake (or biomarker level) and outcomes. These include high strength of evidence for no effect of or association between marine oil intake and major adverse cardiac events (MACE), all-cause mortality, sudden cardiac death (SCD), coronary revascularization, or BP; moderate strength of evidence of no association between marine oil intake and atrial fibrillation (AFib), and between DHA intake and BP or LDL-c, and between alphalinolenic acid (ALA) and BP, LDL-c, HDL-c, or Tg; and low strength of evidence of no association between total n-3 FA intake and stroke death or myocardial infarction (MI); between marine oil intake and CVD death, coronary heart disease (CHD) death, total CHD, MI, angina pectoris, CHF, total stroke or hemorrhagic stroke; between EPA intake and CHD; between EPA biomarkers and AFib; between DHA intake and CHD; between docosapentaenoic acid (DPA) biomarkers and AFib; and between ALA intake and CHD, CHD death, AFib, or CHF. Analyses of n-3 FA and outcome pairs not included in the table provided insufficient evidence.

Table 55 Main findings of high, moderate, or low strength of evidence of no significant effects or associations between omega-3 fatty acids and outcomes

There is high strength of evidence of no effect or association of n-3 FA intake or biomarker level and the following outcomes:; - Marine oil^*^ supplementation (or increased dietary intake) and risk of major adverse cardiovascular event (MACE); ○ RCTs (of mostly supplements); observational studies (of total dietary intake) also found no significant associations; ○ Summary effect size (RCTs): 0.96 (95% CI 0.91, 1.02); - Marine oil^*^ supplementation (or increased dietary intake) and all-cause death; ○ RCTs (of mostly supplements) supported by observational studies (of total dietary intake); ○ Summary effect size (RCTs): 0.97 (95% CI 0.92, 1.03); ○ Observational studies (of total dietary intake): 0.62 (95% CI 0.31, 1.25) per g/d; - Marine oil^*^ supplementation (or increased dietary intake) and sudden cardiac death (SCD); ○ RCTs (of mostly supplements) supported by an observational study (of total dietary intake); ○ Summary effect size (RCTs): 1.04 (95% CI 0.92, 1.17); - Marine oil^*^ supplementation (or increased dietary intake) and coronary revascularization; ○ RCTs (of mostly supplements) supported by an observational study (of total dietary intake); - Marine oil^*^ supplementation (or increased dietary intake) and systolic or diastolic blood pressure; ○ RCTs (of mostly supplements); ○ Summary net change in systolic blood pressure: 0.1 mg/dL (95% CI −0.2, 0.4); ○ Summary net change in diastolic blood pressure: −0.2 mg/dL (95% CI −0.4, 0.5)
There is moderate strength of evidence of no effect or association of n-3 FA intake or biomarker level and the following outcomes:; - Marine oil^*^ supplementation (or increased dietary intake) and atrial fibrillation; ○ RCTs (of mostly supplements); observational studies of intake were inconsistent; - Purified DHA supplementation and systolic or diastolic blood pressure; ○ RCTs (of supplements only); - Purified DHA supplementation and LDL-c; ○ RCTs (of supplements only); - ALA supplementation (or increased dietary intake) and systolic or diastolic blood pressure; ○ RCTs (of mostly supplements); - ALA supplementation (or increased dietary intake) intake and LDL-c, HDL-c, and Tg; ○ RCTs (of mostly supplements)
There is low strength of evidence of no effect or association of n-3 FA intake or biomarker level and the following outcomes:; - Total n-3 FA higher dietary intake and stroke death; ○ Observational studies (of total dietary intake and biomarkers); - Total n-3 FA higher dietary intake and myocardial infarction; ○ Observational studies (of total dietary intake); - Marine oil^*^ supplementation (or increased dietary intake) and cadiovascular death (CVD) death; ○ Summary effect size (RCTs): 0.92 (95% CI 0.82, 1.02)^†^; ○ Observational studies (of total dietary intake): 0.88 (95% CI 0.82, 0.95) per g/d; - Marine oil^*^ supplementation (or increased dietary intake) and coronary heart disease (CHD) death; ○ RCTs (of mostly supplements) imprecise; ○ Observational studies (of total dietary intake): 1.09 (95% CI 0.76, 1.57) per g/d; - Marine oil^*^ higher dietary intake and coronary heart disease (CHD); ○ Observational studies (of total dietary intake), supported by a single study of n-3 FA biomarkers; ○ Observational studies (of total dietary intake): 0.94 (95% CI 0.81, 1.10) per g/d; - Marine oil^*^ supplementation (or increased dietary intake) and myocardial infarction; ○ Summary effect size (RCTs): 0.88 (95% CI 0.77, 1.02)^†^; - Marine oil^*^ supplementation and angina pectoris; ○ RCTs (of supplements) with heterogeneous outcomes (definitions of angina pectoris); - Marine oil^*^ supplementation (or increased dietary intake) and congestive heart failure CHF; ○ RCTs (of mostly supplements) imprecise and could not be meta-analyzed, all nonsignificant; ○ Observational studies (of total dietary intake) significant by metaregression: 0.76 (95% CI 0.58, 1.00) per g/d (P<0.05); - Marine oil^*^ supplementation (or increased dietary intake) and total stroke (fatal and nonfatal ischemic and hemorrhagic stroke); ○ Summary effect size (RCTs): 0.97 (95% CI 0.83, 1.13); ○ Observational studies (of total dietary intake): 0.68 (95% CI 0.53, 0.87) per g/d; - Marine oil^*^ higher dietary intake and hemorrhagic stroke; ○ Observational studies (of total dietary intake): 0.61 (95% CI 0.34, 1.11) per g/d; - EPA higher dietary intake and CHD; ○ Observational studies (of total dietary intake); - EPA higher biomarker levels and atrial fibrillation; ○ Observational studies (of biomarkers); - DHA higher dietary intake and CHD; ○ Observational studies (of total dietary intake and biomarkers); - DPA higher biomarker levels and atrial fibrillation; ○ Observational studies (of biomarkers); - ALA higher dietary intake and CHD death and, separately, total CHD; ○ Observational studies (of total dietary intake); CHD death finding supported by one RCT (of supplementation) and one observational study of biomarkers; ○ Observational studies (of total dietary intake): CHD death 0.94 (95% CI 0.85, 1.03) per g/d; ○ Observational studies (of total dietary intake): CHD 0.97 (95% CI 0.92, 1.03) per g/d; - ALA higher dietary intake and atrial fibrillation; ○ Observational studies (of total dietary intake and biomarkers); - ALA supplementation (or increased dietary intake) and congestive heart failure (CHF); ○ Observational studies (of total dietary intake and biomarkers), supported by one RCT (of supplementation)

* Statements about “marine oil” are based on all evidence of analyses of EPA+DHA+DPA, EPA+DHA, EPA, DHA, and DPA as supplements (e.g., fish oil) or as components of dietary intake (e.g., from fatty fish).

† There is low confidence that this summary estimate would remain suggestive of no effect with the addition of future trial data (and greater statistical power).

Abbreviations: ALA = alphalinolenic acid, CHD = coronary heart disease, CHF = congestive heart failure, DHA = docosahexaenoic acid, DPA = docosapentaenoic acid, EPA = eicosapentaenoic acid, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, MACE = major adverse cardiovascular event (including cardiac and stroke events and death; variously defined by studies), n-3 FA = omega-3 fatty acids, RCT = randomized controlled trial, SCD = sudden cardiac death, Tg = triglycerides.

Studies within each category of analysis (by study design and by n-3 FA) were diverse, due to differences in outcomes evaluated, definitions of specific outcomes, as well as the n-3 FA intervention doses or compositions (for RCTs) or the dietary/biomarker n-3 FA exposure assessments and quantifications (for observational studies). Overall we found a lack of conclusive or consistent findings for CVD events within RCTs, mostly due to sparse data and underpowered trials as indicated by wide confidence intervals. The majority of the individual RCTs did not find statistically significant effects of marine oil supplements (EPA+DHA, various doses) on CVD outcomes. Pooled meta-analyses suggest that people with CVD or at risk for CVD who received marine oil supplements may have a small risk reduction in CVD death (pooled HR 0.92; 95% CI 0.82 to 1.02) compared with those who received placebo. Across outcomes, the effects of marine oil supplements were often larger in earlier RCTs than in more recent RCTs. These data may be confounded by shifts over time in concomitant therapy to reduce CVD risk (e.g., statins, aspirin), decreasing smoking rates, and overall declining rates of CVD events. No meta-regression across studies found significant changes in effect sizes by publication year; however, it is likely that all such meta-regressions of clinical outcomes were underpowered due to relatively small numbers of trials.

Observational studies were mixed regarding the associations between n-3 FA intake or biomarkers and risk of MACE (where each study used its own combination of specific CVD outcomes). The strength of associations between higher levels of n-3 FA and lower risk of CVD outcomes, when found, were often larger than those in RCTs. While all observational studies adjusted associations for potentially confounding variables, the specific variables included in models varied greatly across observational studies. Furthermore, all observational studies compared higher intake levels of n-3 FA with lowest intake level, which included people who may have other nutrition deficiencies that may affect chronic disease risks but often cannot be “controlled for” in the analyses (resulting in residual, uncontrolled confounding).

The overall findings for the effects of marine oil supplements on intermediate CVD outcomes remain largely unchanged since the original report. In this update, there were no significant effects found in 29 RCTs that compared marine oils (0.3–6 g/d) on systolic or diastolic BP compared with placebo. Thirty-three RCTs evaluated LDL-c and HDL-c. Meta-analyses of the effect of marine oils on HDL-c and LDL-c found small, but statistically significant amounts (summary net change HDL-c = 1.2 mg/dL [95% CI 0.6 to 1.8]; LDL-c = 2.0 mg/dL [95% CI 0.4 to 3.6]). The clinical significance of these small increases in both HDL-c and LDL-c on CVD outcomes, particularly in combination, is unclear. For both lipids, no differences in effect across studies were found by marine oil dose, followup duration or population. The strongest effect of marine oils (0.3–6 g/d) was found among the 40 RCTs of Tg. Meta-analysis found a summary net change of −23 mg/dL (95% CI −29 to −18), with no significant difference in effect based on population or followup time across studies. However, across trials, the effect was dose-dependent and also dependent on the studies’ mean baseline Tg values. By metaregression, each increase of EPA+DHA dose by 1 g/d was also associated with a greater net change Tg of −6.8 mg/dL (95% CI −11.4 to −2.2) and each increase in mean baseline Tg level by 1 mg/dL was associated with a greater net change Tg of −0.12 mg/dL (95% CI −0.22 to −0.03). However, the few trials that directly compared marine oil doses did not consistently find a dose effect; although, marine oil doses ≥3 g/d all resulted in larger reductions in Tg compared to lower doses, in contrast to doses <3 g/d which had smaller reductions in Tg compared to even lower doses. There were no observational studies evaluating these intermediate CVD outcomes.

In the original report, there was only one RCT of ALA (linseed oil) versus control oil (sunflower seed oil),49 conducted in the 1960s, that evaluated clinical event outcomes. In this update we identified only one additional RCT of ALA (plant source not reported) versus placebo (oleic acid) in participants with a history of MI that reported clinical outcomes.119 Given the sparseness of trials of the effect on clinical CVD outcomes of higher ALA intake and the differences between the two trials, no conclusion can be drawn regarding effect of ALA on CVD outcomes. For intermediate outcomes, five ALA RCTs (with doses ranging from 1.4 to 5.9 g/d) evaluated BP outcomes, and four of the five RCTs also evaluated LDL-c, HDL-c, Tg, or Total:HDL-c ratio (2 trials) outcomes. All found no significant differences in these outcomes between ALA and placebo. Thirteen observational studies evaluated ALA intake. The large majority of analyses found no significant associations; only two studies found any significant associations between higher ALA intake and clinical outcomes (reduced all-cause death, SCD, and CHD death risks).

The potential threshold-effects of n-3 FA on CVD events could not be determined from the RCTs because there were limited number of RCTs for many outcomes and most RCTs did not find significant effects. Only for Tg is there evidence among trials of a dose effect, such that higher dose marine oils result in greater reductions in Tg. Using data from observational studies, the linear dose-response and potential threshold effects of n-3 FA on several CVD events were tested by meta-analytical techniques. There was a near-significant association between EPA and DHA intake and CHD across a median dose range of 0.04 to 3.47 g/d (effect size per g/d = 0.90 [95% CI 0.80 to 1.01]), and a just-significant association between EPA and DHA intake and higher risk of ischemic stroke across a median dosage range of 0.025 to 0.6 g/d (effect size per g/d = 1.03 [95% CI 1.00 to 1.07]), but no dose-response relationships found between EPA and DHA intake and hemorrhagic stroke. The interpretations of the threshold-effects were limited because differences in associations at lower doses (statistically significant associations between higher intake and lower risk) and associations at higher doses (no significant associations between intake and outcome) were generally similar regardless of the cut point chosen between lower and higher dose analyses.

No differences in effects or associations were found between different populations (healthy or general population, at increased risk for CVD—largely due to dyslipidemia, or with CVD). However, this conclusion is weak given that few studies compared populations, few RCTs were conducted in healthy populations and few observational studies were conducted in at risk or CVD populations.

## Limitations

Overall, both RCTs and observational studies (i.e., longitudinal observational and nested case-control studies) included in this systematic review generally had few risk of bias concerns. Across RCTs, the most common risk of bias limitation was a lack of intention-to-treat analyses (25% of the included RCTs). Of included RCTs, 18 percent could not blind study participants because the intervention was dietary (increased fish intake, not n-3 FA supplements), and 15 percent of RCTs were at risk of attrition bias primarily due to overall dropout rates greater than 20 percent. Most studies reported similar dropout rates between groups. Although more than 90 percent of the included RCTs reported similar baseline demographic characteristics between groups, about 40 percent did not report baseline n-3 FA intake or status. This is a critical point because baseline n-3 FA status likely affects response to changes in n-3 FA intake (diet or supplements). Across observational studies, the most common risk of bias limitation was reporting inadequacy related to the ranges and distribution of n-3 FA exposures (45% did not fully report such data). Of included observational studies, 12 percent did not report the dietary assessment instrument, and most of the n-3 FA dietary intake assessment included only dietary sources (not n-3 FA supplements). At best, studies reported that they used a food frequency questionnaire to estimate n-3 FA intake, without complete details. Of those studies that reported biomarker data, this is not an issue of concern. However, a variety of different n-3 FA biomarkers were investigated across studies, making comparisons and meta-analysis difficult.

For clinical CVD outcomes, all but one of the RCTs was conducted in either high risk individuals or people with existing CVD. In contrast, most observational studies examining the associations between dietary n-3 FA intake or biomarkers of n-3 FA intake and clinical outcomes were conducted in generally healthy populations. The definitions of most clinical outcomes were heterogeneous across studies regardless of the study designs. For most clinical outcomes, there were few or no RCTs. Few trials compared n-3 FA dose, formulation, or source. No trial compared different n-3 to n-6 FA ratios of supplements or intake. None of the observational studies attempted to determine a threshold effect of any associations between n-3 FA and the outcome of interest.

Other study-reporting issues that precluded analyses from being included in meta-analyses were that studies of n-3 FA intake used a variety of methods to measure intake (g/d, percent Kcal, percent fat or fatty acid intake); several studies failed to report median or range data of n-3 FA levels within quantiles, confidence intervals (or equivalent) of association hazard ratios, or conducted only linear analyses across a full range of n-3 FA values. In addition, studies varied in the range of n-3 FA status (e.g., intake level) within each study, often with n-3 FA ranges that did not or hardly overlapped. All of the observational studies measured dietary n-3 FA intake or biomarkers of n-3 FA intake at a single time point, baseline, and related these data to the long-term (mostly >10 years) clinical outcomes (CVD events). These analyses rely on the assumption that baseline intake reflects long-term intake, both prior to the beginning of the study and during the course of the observational period. In adults, the relative stability of dietary patterns may minimize the bias due to changing dietary patterns. However, study participants may have changed their dietary or supplement intake of n-3 FA due to concerns about CVD, due to advancing age or new CVD risk factors (e.g., new diagnoses of hypertension, diabetes, or dyslipidemia). These potential dietary changes are unlikely to have occurred at random and may, therefore, introduce bias due to the differential misclassifications of exposure status. This review included neither weight-loss intervention studies nor did we evaluate weight change as an outcome. We also did not include post hoc subgroup analyses (with subgroups defined by status at study end; e.g., by weight loss). Very few, if any, eligible studies evaluated weight change or its interaction with CV-related outcomes. Therefore, this review cannot comment on any potential interactions between weight change and n-3 FA status on CV outcomes.

There are numerous differences between RCTs and observational studies, making the comparisons across the two study designs difficult to make. Of note, the doses of marine oil supplements (EPA+DHA) in RCTs were often much higher than the highest intake reported for observational studies. Furthermore, not all observational studies explicitly included n-3 FA supplements in their assessment of intake and very few of the RCTs attempted to account for background fish or n-3 FA intake as an effect modifier.

Due to significant clinical heterogeneity across studies, the interpretation of overall meta-analysis results is limited. Dose-response meta-analysis of observational studies should be interpreted with caution as many factors many invalidate the results such as heterogeneity in the covariate adjustments across studies and errors or biases in dietary assessments.

While this report represents a complete systematic review, it does not encompass all trials or longitudinal observational studies that report on CVD and intermediate outcomes. Particularly, if one includes small studies (trials with <30 participants per study group or observational studies with <100 participants, several hundred more studies could potentially have met eligibility criteria. Due to time and resource limitations, we restricted the review to the approximately 100 studies that are most likely to have adequately addressed the primary research questions of interest.

## Future Research Recommendations

Future RCTs should characterize the preparations of n-3 FA and placebo used for the intervention in terms of the FA composition and molecular form of the FA (e.g., ethyl esters, Tg), as well as indicating their sources. Of potential interest in future studies is whether effects differ based on these factors. The placebo foods and oils should have the same caloric density and to the extent possible similar food or oil types as the source of n-3 FA. The composition of the background diet should also be reported, as should FA composition, macronutrient content and whether the participants were weight-stable. Researchers are encouraged to use standard, common CVD outcomes to allow comparison across studies. Assessment of n-3 FA status and intake should be evaluated at study entry and post-intervention in all study participants using to better understand potential changes in n-3 FA intake in populations with different background diets (e.g., whether the effect of supplementation differs in people with high- or low-fish diets). If trials include participants with a broad range of n-3 FA status or intake (e.g., with both high- and low-fish diets), subgroup analyses should be conducted to evaluate possible differential effects based on these variables. The effects (or lack thereof) of marine oils (EPA+DHA) on BP, LDL-c, HDL-c, and Tg are well established so additional RCTs on these intermediate outcomes alone are unlikely to add any new knowledge, and therefore are not recommended.

There is an ongoing need to improve self-reported dietary assessment methods and food databases for all nutrients including n-3 FA. As national dietary patterns shift and new processed foods are introduced into the marketplace, food composition tables used to analyze food frequency questionnaire data need to be updated to ensure accurate estimation of n-3 FA (and other nutrient) intake. Similar to trial registries, a data repository for raw observational study data would greatly improve the transparency of data analyses (potentially reduce both reporting and publication biases) and the appropriateness and methodology of meta-analytical techniques for pooling observational studies. An individual participant-level meta-analysis of observational studies of marine oils could address limitations of the study-level meta-analyses that are currently feasible.

## Conclusions

Results from the RCTs of clinical event outcomes are applicable only to at risk of CVD and CVD populations. Results from the RCTs of intermediate outcomes are applicable to all populations. In contrast, results from observational studies (which did not evaluate intermediate outcomes) are applicable only to generally healthy populations. We graded the strength of the body of evidence for each intervention/exposure and comparison of intervention, and for each outcome by assessing the number of studies, their study designs, the study limitations (i.e., risk of bias and overall methodological quality), the directness of the evidence to the Key Questions, the consistency of study results, the precision of any estimates of effect, the likelihood of reporting bias, and the overall findings across studies. We concluded that there is insufficient evidence regarding the effect of or association between total n-3 FA (ALA + marine oils [EPA+DHA+DPA) and clinical or intermediate outcomes. There is low strength of evidence of no association between total n-3 FA intake and stroke death, and total (fatal and nonfatal) MI (each association based on longitudinal observational studies). For marine oil (EPA+DHA±DPA), there is insufficient evidence for most outcomes of interest but there is low to high strength of evidence of a beneficial effect of higher marine oil intake for selected CVD and intermediate outcomes. Specifically, there is high strength of evidence of that marine oils clinically and statistically significantly lower Tg—possibly with greater effects with higher doses and in people with higher baseline Tg—and statistically, but arguably not clinically, significantly raises HDL-c. There is also high strength of evidence that marine oil significantly lowers Total:HDL-c ratio. There is moderate strength of evidence that marine oil supplementation lowers risk of MACE events and total CVD death. There is a high strength of evidence of no effect of marine oil on risk of total stroke (ischemic and hemorrhagic, fatal and nonfatal), but low strength of evidence of no associations of marine oil intake and ischemic or hemorrhagic stroke. There is low strength of evidence for associations between higher EPA+DHA intake and decreased risk of CHD and CHF, based on observational studies. However, there is moderate to high strength of evidence of no effect of (or association between) marine oil and all-cause death, MI, AFib, CHF, SCD, revascularization, BP, LDL-c, or LDL:HDL-c ratio. There is also low strength of evidence of no effect of marine oil intake and CHD death.

For individual n-3 FA, there is insufficient evidence regarding the effect of or association with EPA, DHA, DPA, stearidonic acid (SDA), or ALA (specifically) and most CVD clinical outcomes. For EPA, there is low strength of evidence of no association between EPA intake and CHD and between EPA biomarkers and AFib. For DHA, there is moderate strength of evidence of no effect of purified DHA supplementation on BP or LDL-c and low strength of evidence of no association between DHA intake and incident CHD (from observational studies). For DPA (no RCT was identified), there is low strength of evidence of an association between higher DPA biomarker levels and lower risk of AFib. For ALA, there is moderate strength of evidence of no significant effect of ALA intake on BP, LDL-c, HDL-c, or Tg. There is low strength of evidence of no association between ALA intake or biomarker level and CHD or CHD death, AFib, CHF, total and ischemic stroke, based on observational studies.

There is insufficient evidence of direct comparisons between marine oil and ALA intake on CVD outcomes. Across studies, the comparison between marine oil and ALA is unclear, largely because of insufficient evidence regarding ALA; however, where there is high strength of evidence of significant effects of marine oil on improving Tg and HDL-c, there is moderate strength of evidence of no effect of ALA intake on these intermediate outcomes. No RCTs examined the additive effects of n-3 FA versus the effects of individual n-3 FA.

In the scientific community, there is a perception of “conflicting evidence” for the role of n-3 FA in prevention or treatment of CVD between RCT and observational study data.196, 197 This perception may in part stem from inconsistent scientific conclusions among several of the expert panels or may relate to whether the potential beneficial effects of n-3 FA were from fish (or other marine foods) intake or from dietary supplements.5–8 Our qualitative comparisons between RCTs and observational studies (i.e., longitudinal observational and nested case-control studies) included in this systematic review showed that the evidence base from the two study designs relating n-3 FA to CVD outcomes often are not comparable as they address different research questions. It is important to note that observational studies of fish consumption without quantifications of n-3 FA were not included in this systematic review. Our findings highlight the importance of including both observational studies and RCTs to assess the strength of body of evidence because the two study designs each have their own strengths and weakness and often provide complementary pieces of information for causal inferences. Nutrition observational studies typically measure and compare people with different dietary behaviors (thus different levels of nutrient exposure) in relationship to the disease risks, while nutrition RCTs are typically designed to compare a specific (usually narrowly defined) nutrition intervention to a control) in a relatively homogenous and well-defined study population. By design, nutrition observational studies and RCTs address different research questions. The observed relationships between higher or lower levels of intake and disease risks are important to describe potential behavioral target for interventions for prevention or treatment of a disease but will never be sufficient to pin point the specific mechanism or doses for the interventions. Therefore it is unlikely that a RCT can be designed to “verify” or “validate” nutrition observational results. On the other hand, RCTs are the most valid design for comparative effectiveness research questions. Long-term nutrition RCTs, however, often suffer compliance or contamination issues that can void the advantages of initial randomization. No single study can provide a “definitive answer” due to the unique challenges in nutrition RCTs and observational studies. It is necessary to carefully review the totality of evidence while considering the strengths and limitations of the individual studies.