# Appendix G Causality Tables

Appendix G.1 Causality Table: Comparative Studies

Appendix G.2 Causality Table: Observational Studies