# Appendix F Observational results

Appendix F Observational results: acute coronary syndrome

Appendix F Observational results: atrial fibrillation

Appendix F Observational results: sudden coronary death

Appendix F Observational results: hypertension

Appendix F Observational results: coronary heart disease

Appendix F Observational results: congestive heart failure

Appendix F Observational results: myocardial Infarction

Appendix F Observational results: stroke

Appendix F Observational results: hemorrhagic stroke

Appendix F Observational results: ischemic stroke

Appendix F Observational results: major adverse cardiac events

Appendix F Observational results: coronary artery bypass graft surgery

Appendix F Observational results: all-cause death

Appendix F Observational results: cardiac death

Appendix F Observational results: death from coronary heart disease

Appendix F Observational results: death from cardiovascular disease

Appendix F Observational results: death from congestive heart failure

Appendix F Observational results: death from myocardial infarction

Appendix F Observational results: death from stroke

Appendix F Observational results: death from hemorrhagic stroke

Appendix F Observational results: death from ischemic stroke

Appendix F Observational results: blood pressure