# Appendix E Study Design

Table E-1 Comparative studies

Table E-2 Observational studies