# Appendix D Baseline Characteristics

Table D-1 Comparative studies, continuous measures

Table D-2 Comparative studies, categorical measures

Table D-3 Baseline Omega-3 intake, comparative studies

Table D-4 Observational studies, continuous measures

Table D-5 Observational studies, categorical measures