# Appendix C Risk of Bias Assessment

Table C-1 Comparative studies

Author, Year PMID* | Randomization: allocation sequence adequately generated | Allocation adequately concealed | Participants adequately blinded | Outcome assessors adequately blinded | Attrition bias: Incomplete outcome data | Selective outcome reporting bias (Yes/No) | Intention-to-treat analysis? (Yes/No) | Group similarity at baseline (general) | Group similarity at baseline (Omega-3) | Similar compliance across groups | Additional bias
Baxheinrich, 2012, 22894911 | Unclear | Unclear | High | Low | Low | No | No | Low | Unclear | High
Bosch, 2012, 22686415 | Unclear | Low | Low | Low | Low | No | No | Low | Low | Unclear
Brinton, 2013, 22819432 23835245 | Unclear | Low | Low | Low | Low | No | Yes | Low | Unclear | Unclear
Brouwer, 2006, 16772624 | Low | Low | Low | Low | Low | No | Yes | Low | Low | Low
Burr, 2003, 12571649 17343767 | Unclear | Low | High | Low | Low | No | Yes | Low | Low | Low
Burr, 1989, 2571009 10578215 12032650 | Unclear | High | High | High | Low | Yes | Yes | Low | Unclear | Low
Carrepeiro, 2011, 21561620 | Unclear | Unclear | Low | Low | Low | No | No | Low | Unclear | Low | Yes (Statin subgroups treated as randomized factors, but really just matched. Matching failed to make baseline lipoprotein concentrations similar.)
Carter, 2012, 22707560 | Unclear | Unclear | Low | Unclear | Low | No | Yes | Low | Unclear | Unclear
Caslake, 2008, 18779276 | Low | Unclear | Low | Low | Low | No | Unclear | Low | Low | Low
Damsgaard, 2008, 18492834 | Low | Low | Low | Low | Low | No | Yes | Low | Low | Low
Derosa, 2009, 19397392 | Low | Low | Low | Low | Low | No | Yes | Low | Unclear | Unclear
Earnest, 2012, 22811376 | Low | Low | Low | Low | Low | No | No | Low | Low | Unclear
Ebrahimi, 2009, 19593941 | Unclear | Unclear | Unclear | Low/High for BP | Unclear | No | Unclear | Low | Unclear | Unclear
Einvik, 2010, 16926660 19595382 20389249 | Low | Unclear | Low | Low | Low | No | Yes | Low | Low | Low
Eritsland, 1996, 7702027 8540453 | Unclear | Low | Unclear | Unclear | Low | No | Yes (death); No (lipids) | Low | Low | Low
Finnegan, 2003, 12663273 | Low | Low | Low | Low | Low | No | No | Low | Low | Low
Galan, 2010, 18544171 21115589 21801476 22365647 | Low | Low | Low | Unclear | Low | No | Yes | Low | Low | Low
Grieger, 2014, 24454276 | Unclear | Unclear | High | Unclear | Low | No | Yes | Low | Low | Low
Grimsgaard, 1998, 9280188 9665096 | Low | Unclear | Low | Low | Low | No | No | Low | Unclear | Low
Harrison, 2004, 15853118 | Low | Low | Low | Low | High | No | Yes | Low | High | Low
Holman, 2009, 19002433 21036355 | Low | Low | Low | Low | Low | Yes | No | Low | Low | Low
Jones, 2014, 24829493 | Low | Low | Low | Low | High | No | Unclear | Low | Low | Low
Kastelein, 2014, 24528690 | Unclear | Unclear | Low | Unclear | Low | No | Yes | Low | Low | High
Kromhout, 2010, 20362710 20929341 22110169 22301766 | Low | Low | Low | Low | Low | No | Yes | Low | Low | High
Kuhnt, 2014, 24553695 | Low | Low | Low | Low | Low | No | No | Low | Low | Unclear
Leaf, 2005, 16267249 | Low | Unclear | Low | Low | Low | No | Yes | Low | Low | Low
Liu, 2003, no PMID | Unclear | Unclear | Unclear | Low | Low | No | Yes | Low | Low | Low
Lungershausen, 1994, 7852747 | Low | Unclear | Low | Unclear | Low | No | Yes | Low | Unclear | Low
Macchia, 2013, 23265344 | Unclear | Low | Low | Low | Unclear | No | No | Low | Unclear | Unclear
Maki, 2010, 17825687 20451686 | Low | Low | Low | Low | Low | No | Yes | High | Unclear | Low
Maki, 2013, 23998969 | Unclear | Unclear | Low | Low | High | No | Yes | Low | Low | Low
Marchioli, 2002, 10465168 11997274 17876196 | Low | Unclear | High | Unclear | Low | No | Yes | Low | Unclear | Low
Natvig, 1968, 5756076 | Unclear | Low | Low | High | High | No | Yes | Unclear | Low | Low
Nilsen, 2001, 11451717 15297084 | Low | Low | Low | Low | High | Yes | Yes | Low | Unclear | Unclear
Nodari, 2011, 21844082 | Low | Low | Low | Low | Unclear | No | No | Low | Unclear | Unclear
Nodari, 2011, 21215550 | Unclear | Unclear | Low | Low | Low | No | Yes | Low | Low | Low
Oh, 2014, 25147070 | Low | Low | Low | Low | Low | No | Unclear | Low | Unclear | Unclear
Olano-Martin, 2010, 19748619 | Unclear | Unclear | Low | Low | Low | No | Unclear | Low | Low | Low
Pase, 2015, 25565485 | Low | Low | Low | Low | Low | Yes | Yes | Low | Low | Low
Pieters, 2015, 25226826 | Unclear | Unclear | Low | Low | Low | No | No | Low | Low | Low
Raitt, 2005, 15956633 | Unclear | Low | Low | Low | Low | No | No | Low | Unclear | Unclear
Ras, 2015, 25122648 | Low | Low | Low | Low | Low | Yes | Yes | Low | Unclear | Low
Rasmussen, 2006, 16469978 | Low | Low | High | Low | Low | No | Yes | Low | Low | Low
Rauch, 2010, 21060071 | Low | Low | Low | Low | Low | No | Yes | Low | Unclear | Low | Unclear (High underlying levels of fish consumption during the study could have influenced the clinical event rate during followup.)
Rodriguez-Leyva, 2013, 24126178 25694068 | Low | Low | High | Low | Low | No | Yes | Low | Low | Low
Roncaglioni, 2013, 23656645 | Low | Low | Low | Low | Low | No | Yes | Low | Low | Low
Sacks, 1994, 8021472 | Unclear | Low | Low | Low | High | Yes | No | Unclear | Low | Low
Sacks, 1995, 7759696 | Unclear | Low | Low | Low | High | No | Yes | Low | Low | Low
Sanders, 2011, 21865334 | Low | Low | Low | Low | Low | No | No | Low | Low | Low
Shaikh, 2014, 25185754 | Low | Low | Low | Low | High | No | No | Low | Low | Low
Shidfar, 2003, 12847992 | Unclear | Unclear | Low | Low | High | No | Unclear | Low | Unclear | Unclear
Sirtori, 1997, 9174486 | Low | Unclear | Low | Low | Low | No | Yes | Low | Unclear | High
Soares, 2014, 24652053 | Unclear | Unclear | Low | Unclear | Low | Yes | No | Low | Unclear | Unclear
Tardivo, 2015, 25394692 | Low | Unclear | High | High | High | No | Unclear | Low | Low | Unclear
Tatsuno, 2013, 24314359 | Low | Unclear | High | High | Low | Yes | Yes | Low | Low | Low
Tatsuno, 2013, 23725919 | Low | Unclear | High | High | Low | Yes | Yes | Low | Low | Low
Tavazzi, 2008, 18757090 19589110 21315217 23351824 23839902 | Low | Low | Low | Low | Low | Yes | Yes | Low | Low | Low
Tierney, 2011, 20938439 21839455 | Low | Low | High | Low | Low | No | Yes | Low | Low | Low
Vazquez, 2014, 24462043 | Low | Low | Low | Low | Low | No | Yes | Low | Unclear | Low
Vecka, 2012, 23183517 | High | Unclear | Low | Unclear | Unclear | No | Yes | Low | Low | Unclear
von Schacky, 1999, 10189324 | Low | Low | Low | Low/High for BP | Low | No | Yes | Low | Low | Low
Yokoyama, 2007, 17398308 18451347 18667204 19423946 20484828 22186099 22653220 | Low | Low | High | Low | Low | No | Yes | Low | Unclear | Unclear

PMID = Pubmed identifiers of all included articles.

Table C-2 Observational studies

Study PMID | Selection bias (outcome of interest not present at baseline) | Comparability/Adjustment (adjusted for confounders or other factors) | Outcome assessors adequately blinded | Incomplete outcome data (attrition bias) | Dietary assessment instrument described (studies with FFQ)? | Nutrient exposures adequately reported | Additional Bias
Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study 9149659 | Unclear | Yes (Diet and CVD risk factors) | Low | Unclear | Yes (Measured n-3 FA from ONLY diet) | No
ARIC 19061714 22570739 23920478 | Low | No | Low | Unclear | Not Applicable (biomarker) | No
CARDIA 21205024 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | No
Cardiovascular Health Study 21810709 22282329 22743310 23525429 23546563 25159901 | Low | Yes (Diet and CVD risk factors) | Low | Low | Not Applicable (biomarker) | Yes
Cohort of Swedish Men 19383731 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from BOTH diet and supplements) | No
Danish National Birth Cohort 22146511 | Unclear | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
Diet, Cancer and Health 15640459 19825219 21859970 23945170 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
EPIC Norfolk 22802735 | Low | Yes (Diet and CVD risk factors) | Low | Low | Not Applicable (biomarker) | No
Glostrup Population Studies 21865326 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
Guangzhou 24966412 | Low | Partial (Diet factors) | Low | Low | Not Applicable (biomarker) | Yes
Healthy Physicians Follow-up Study 7885425 12495393 19064523 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from BOTH diet and supplements) | Yes
Hisayama Study 24267237 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
JACC 18786479 | Low | Yes (Diet and CVD risk factors) | Unclear | High | Yes (Measured n-3 FA from ONLY diet) | Yes
Japan Public Health Center-Based Study Cohort I 16401768 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | No
JELIS 21099130 | Low | Yes (Diet and CVD risk factors) | Unclear | Low | Not Applicable (biomarker) | No
Kuopio Ischemic Heart Disease Risk Factor Study 19933935 | Low | Partial (Diet factors) | Low | Low | Not Applicable (biomarker) | Yes
Malmo Diet and Cancer 25008580 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from BOTH diet and supplements) | No
MESA 24351702 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
MORGEN 20335635 21464993 22496770 22633188 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
MRFIT 1579579 | Unclear | Partial (CVD risk factors) | Low | Unclear | Yes (Instrument reported but no adequate description regarding n-3 FA intake measurement) | No
NIPPON DATA80 24468152 | Low | Partial (CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
Nurses’ Health Study 11176840 11939867 16301356 | Low | Yes (Diet and CVD risk factors) | High | Low | No (No data on instrument or method used to measure n-3 FA intake) | Yes
Osaka Acute Coronary Insufficiency Study 23047296 | Low | No | Unclear | Low | Not Applicable (biomarker) | Yes
Physician’s Health Study 7598116 7829792 9424039 22952185 23098619 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
Pooling Project of Cohort Studies on Diet and Coronary Disease 24964401 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (nd for whether n-3 measured from both diet and supplements) | Yes
Rotterdam Study 16569549 19789394 | Low | Yes (Diet and CVD risk factors) | Low | Unclear | Yes (Measured n-3 FA from BOTH diet and supplements) | Yes
Scottish Heart Health Extended Cohort Study 21345851 | Low | Partial (CVD risk factors) | Low | Low | Yes (Measured n-3 FA from BOTH diet and supplements) | No
Singapore Chinese Health Study 24343844 | Low | Yes (Diet and CVD risk factors) | Unclear | Low | No (No data on instrument or method used to measure n-3 FA intake) | No
Shanghai Study 11682363 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
Shanghai Women’s/Men’s Health Studies 23788668 | Low | Partial (Diet factors) | High | Low | Yes (Measured n-3 FA from ONLY diet) | No | Yes (Difference in followup 11.2 years in women vs. 5.6 in men)
Spanish EPIC 24360762 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | No
Swedish Mammography Study 20332801 22172525 22265275 25679993 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from BOTH diet and supplements) | No
Takayama Study 12397000 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
Uppsala Longitudinal Study of Adult Men 18614742 | Low | Yes (Diet and CVD risk factors) | Low | Low | Not Applicable (biomarker) | Yes
Vitamins and Lifestyle Study 24496442 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | Yes
Women’s Health Initiative 20211329 21610249 | Low | Yes (Diet and CVD risk factors) | Low | Low | Yes (Measured n-3 FA from ONLY diet) | No
Women’s Health Study 20713915 21734059 | Low | Partial (CVD risk factors) | High | Low | Yes (Measured n-3 FA from ONLY diet) | No

PMID = Pubmed identifiers of all included articles.