# Appendix B Excluded Studies

Table B-1 Excluded studies

PMID | Authors | Title | Journal | Rejection Reason
none | L. F. Darghosian et al. | Effect of omega-three polyunsaturated fatty acids on inflammation, oxidative stress, and recurrence of atrial fibrillation | American Journal of Cardiology | <1 yr CVD
none | V. V. E. Lomivorotov and S. M.; Pokushalov and E. A.; Romanov and A. B.; Ponomarev and D. N.; Cherniavsky and A. M.; Shilova and A. N.; Karaskov and A. M.; Lomivorotov and V. N. | Randomized trial of fish oil infusion to prevent atrial fibrillation after cardiac surgery: data from an implantable continuous cardiac monitor | | <1 yr CVD
23890856 | Kumar S and Sutherland F and Stevenson I and Lee JM and Garg ML and Sparks PB | Effects of long-term omega-3 polyunsaturated fatty acid supplementation on paroxysmal atrial tachyarrhythmia burden in patients with implanted pacemakers: results from a prospective randomised study. | International Journal of Cardiology | <1 yr CVD
22128614 | Sorice M1, Tritto FP, Sordelli C, Gregorio R, Piazza L. | N-3 polyunsaturated fatty acids reduces post-operative atrial fibrillation incidence in patients undergoing “on-pump” coronary artery bypass graft surgery. | Monaldi Arch Chest Dis. | <1 yr CVD
22120130 | Kumar S and Sutherland F and Morton JB and Lee G and Morgan J and Wong J and Eccleston DE and Voukelatos J and Garg ML and Sparks PB | Long-term omega-3 polyunsaturated fatty acid supplementation reduces the recurrence of persistent atrial fibrillation after electrical cardioversion. | Heart Rhythm: The Official Journal of the Heart Rhythm Society | <1 yr CVD
21762871 | Farquharson AL1, Metcalf RG, Sanders P, Stuklis R, Edwards JR, Gibson RA, Cleland LG, Sullivan TR, James MJ, Young GD. | Effect of dietary fish oil on atrial fibrillation after cardiac surgery. | Am J Cardiol. | <1 yr CVD
21078810 | Kowey PR1, Reiffel JA, Ellenbogen KA, Naccarelli GV, Pratt CM. | Efficacy and safety of prescription omega-3 fatty acids for the prevention of recurrent symptomatic atrial fibrillation: a randomized controlled trial. | JAMA. | <1 yr CVD
21059740 | Bianconi L1, Calò L, Mennuni M, Santini L, Morosetti P, Azzolini P, Barbato G, Biscione F, Romano P, Santini M. | n-3 polyunsaturated fatty acids for the prevention of arrhythmia recurrence after electrical cardioversion of chronic persistent atrial fibrillation: a randomized, double-blind, multicentre study. | Europace. | <1 yr CVD
20061328 | Heidarsdottir R1, Arnar DO, Skuladottir GV, Torfason B, Edvardsson V, Gottskalksson G, Palsson R, Indridason OS. | Does treatment with n-3 polyunsaturated fatty acids prevent atrial fibrillation after open heart surgery? | Europace. | <1 yr CVD
20042769 | Saravanan P1, Bridgewater B, West AL, O’Neill SC, Calder PC, Davidson NC. | Omega-3 fatty acid supplementation does not reduce risk of atrial fibrillation after coronary artery bypass surgery: a randomized, double-blind, placebo-controlled clinical trial. | | <1 yr CVD
19629889 | Heidt MC1, Vician M, Stracke SK, Stadlbauer T, Grebe MT, Boening A, Vogt PR, Erdogan A. | Beneficial effects of intravenously administered N-3 fatty acids for the prevention of atrial fibrillation after coronary artery bypass surgery: a prospective randomized study. | Thorac Cardiovasc Surg. | <1 yr CVD
15253884 | Singer P and Wirth M | Can n-3 PUFA reduce cardiac arrhythmias? Results of a clinical trial. | Prostaglandins, Leukotrienes, and Essential Fatty Acids | <1 yr CVD
12891211 | Geelen A and Zock PL and Swenne CA and Brouwer IA and Schouten EG and Katan MB | Effect of n-3 fatty acids on heart rate variability and baroreflex sensitivity in middle-aged subjects. | American Heart Journal | <1 yr CVD
11303007 | Durrington PN1, Bhatnagar D, Mackness MI, Morgan J, Julier K, Khan MA, France M. | An omega-3 polyunsaturated fatty acid concentrate administered for one year decreased triglycerides in simvastatin treated patients with coronary heart disease and persisting hypertriglyceridaemia. | Heart. | <1 yr CVD
10334433 | Johansen O, Brekke M, Seljeflot I, et al. | N-3 fatty acids do not prevent restenosis after coronary angioplasty: results from the CART study. Coronary Angioplasty Restenosis Trial. | J Am Coll Cardiol. | <1 yr CVD
8840843 | Cairns JA., Gill J., Morton B., Roberts R., Gent M., Hirsh J., Holder D., Finnie K., Marquis JF., Naqvi S., Cohen E. | Fish oils and low-molecular-weight heparin for the reduction of restenosis after percutaneous transluminal coronary angioplasty. The EMPAR Study. | Circulation. 1996 Oct 1;94(7):1553–60. | <1 yr CVD
4161161 | Borchgrevink, 1966 | Absence of prophylactic effect of linolenic acid in patients with coronary heart-disease. | Lancet. 1966 Jul 23;2(7456):187–9. | <1 yr CVD
2568519 | Reis GJ, Boucher TM, Sipperly ME, et al. | Randomised trial of fish oil for prevention of restenosis after coronary angioplasty | Lancet | <1 yr CVD
2537349 | Grigg LE1, Kay TW, Valentine PA, Larkins R, Flower DJ, Manolas EG, O’Dea K, Sinclair AJ, Hopper JL, Hunt D. | Determinants of restenosis and lack of effect of dietary supplementation with eicosapentaenoic acid on the incidence of coronary artery restenosis after angioplasty. | J Am Coll Cardiol. | <1 yr CVD
21466598 | Iggman D and Gustafsson IB and Berglund L and Vessby B and Marckmann P and Riserus U | Replacing dairy fat with rapeseed oil causes rapid improvement of hyperlipidaemia: a randomized controlled study. | Journal of Internal Medicine | <4 wk
15893193 | Calo L and Bianconi L and Colivicchi F and Lamberti F and Loricchio ML and de Ruvo E and Meo A and Pandozi C and Staibano M and Santini M | N-3 Fatty acids for the prevention of atrial fibrillation after coronary artery bypass surgery: a randomized, controlled trial. | Journal of the American College of Cardiology | <4 wk
15591305 | Turvey EA and Heigenhauser GJ and Parolin M and Peters SJ | Elevated n-3 fatty acids in a high-fat diet attenuate the increase in PDH kinase activity but not PDH activity in human skeletal muscle. | Journal of Applied Physiology (Bethesda, Md.: 1985) | <4 wk
14506493 | Roberts WG and Gordon MH and Walker AF | Effects of enhanced consumption of fruit and vegetables on plasma antioxidant status and oxidative resistance of LDL in smokers supplemented with fish oil. | European Journal of Clinical Nutrition | <4 wk; No outcome of interest
none | Nygard OS and E. Pedersen and E. R. Ebbing and M. Svingen and G. Schartum-Hansen and H. Bjorndal and B. Seifert and R. Mayer and K. Nilsen and D. W. Nordrehaug and J. E. | Dietary intake of N-3 long-chain polyunsaturated fatty acids, diabetes mellitus and risk of myocardial infarction in patients with suspected coronary artery disease | Circulation | Abstract only
none | T. A. B. Mori and V. Barden and A. E. Puddey and I. B. Irish and A. B. Cowpland and C. A. Watts and G. F. Beilin and L. J. | 20-Hete contributes to the blood pressure reduction following omega-3 fatty acid supplementation in patients with chronic kidney disease | Journal of Hypertension | Abstract only
none | Y. K. Sun and W. P.; Yuan and J. M.; Choi and H.; Ong and C. N.; Van Dam and R. M. | Circulating omega-3 fatty acids and risk of acute myocardial infarction in Singapore Chinese | Circulation | Abstract only
ABSTRACT | Davidson M, Liebson P, Bagdade J, Messer J, Schoenberger J. | Marine lipid concentrate reduces coronary risk factors: double blind comparison with olive oil | J Am Coll Cardiol 1986;7:247A. | Abstract only
ABSTRACT | M. N. D. Aldin and N. R. T. Carioca and A. A. F. Cartolano and F. D. C. | Omega-3 fatty acid changes size and concentration of lipoproteins of Brazilian subjects included in Cardionutri study | Global Heart | Abstract only
ABSTRACT | R. M. Braeckman and M. S. Ballantyne and C. M. Stirtan and W. G. Soni and P. N. | Effects of AMR101, a pure eicosapentaenoic omega-3 fatty acid, on the fatty acid profile in plasma and red blood cells in statin-treated patients with persistent high triglycerides (results from the anchor study) | Circulation | Abstract only
ABSTRACT | Wilt T, Lofgren R, Nichol K, Schorer A, Crespin L, Eckfeldt J. | Fish oil ingestion does not lower blood pressure in normotensive or hypertensive men | Clin Res 1989;3:916A. | Abstract only
19421317 | Shearer GC1, Pottala JV, Spertus JA, Harris WS. | Red blood cell fatty acid patterns and acute coronary syndrome. | PLoS One. | Case control study
19303975 | Lemaitre RN1, King IB, Sotoodehnia N, Rea TD, Raghunathan TE, Rice KM, Lumley TS, Knopp RH, Cobb LA, Copass MK, Siscovick DS. | Red blood cell membrane alpha-linolenic acid and the risk of sudden cardiac arrest. | Metabolism. | Case control study
18606916 | Campos H1, Baylin A, Willett WC. | Alpha-linolenic acid and risk of nonfatal acute myocardial infarction. | Circulation. | Case control study
17258965 | Lopes C1, Aro A, Azevedo A, Ramos E, Barros H. | Intake and adipose tissue composition of fatty acids and risk of myocardial infarction in a male Portuguesecommunity sample. | J Am Diet Assoc. | Case control study
17223410 | Harris WS1, Reid KJ, Sands SA, Spertus JA. | Blood omega-3 and trans fatty acids in middle-aged acute coronary syndrome patients. | Am J Cardiol. | Case control study
12668490 | Baylin A1, Kabagambe EK, Ascherio A, Spiegelman D, Campos H. | Adipose tissue alpha-linolenic acid and nonfatal acute myocardial infarction in Costa Rica. | Circulation. | Case control study
12530773 | Tavani A, Bertuzzi M, Negri E, Sorbara L, La Vecchia C. | Alcohol, smoking, coffee and risk of non-fatal acute myocardial infarction in Italy. | Eur J Epidemiol. 2001;17(12):1131–7. | Case control study
11839624 | Lemaitre RN1, King IB, Raghunathan TE, Pearce RM, Weinmann S, Knopp RH, Copass MK, Cobb LA, Siscovick DS. | Cell membrane trans-fatty acids and the risk of primary cardiac arrest. | Circulation. | Case control study
11266195 | Sasazuki 2001 Japan | Case-control study of nonfatal myocardial infarction in relation to selected foods in Japanese men and women. | Jpn Circ J. 2001 Mar;65(3):200–6. | Case control study
10195943 | Guallar E1, Aro A, Jiménez FJ, Martín-Moreno JM, Salminen I, van’t Veer P, Kardinaal AF, Gómez-Aracena J, Martin BC, Kohlmeier L, Kark JD, Mazaev VP, Ringstad J, Guillén J, Riemersma RA, Huttunen JK, Thamm M, Kok FJ. | Omega-3 fatty acids in adipose tissue and risk of myocardial infarction: the EURAMIC study. | Arterioscler Thromb Vasc Biol. | Case control study
8503947 | Luostarinen R1, Boberg M, Saldeen T. | Fatty acid composition in total phospholipids of human coronary arteries in sudden cardiac death. | Atherosclerosis. | Case control study
7563561 | Siscovick 1995 US | Dietary intake and cell membrane levels of long-chain n-3 polyunsaturated fatty acids and the risk of primary cardiac arrest. | JAMA. 1995 Nov 1;274(17):1363–7. | Case control study
6279124 | Lea EJ, Jones SP, Hamilton DV. | The fatty acids of erythrocytes of myocardial infarction patients. | Atherosclerosis. | Case control study
4050552 | Skuladottir G, Hardarson T, Sigfusson N, Oddsson G, Gudbjarnason S. | Arachidonic acid levels in serum phospholipids of patients with angina pectoris or fatal myocardial infarction. | Acta Med Scand. | Case control study
2880015 | Wood DA, Riemersma RA, Butler S, Thomson M, Macintyre C, Elton RA, Oliver MF. | Linoleic and eicosapentaenoic acids in adipose tissue and platelets and risk of coronary heart disease. | Lancet. | Case control study
none | S. A. F. H. W. J. T. M. D. P. M. H. K. J. J. P. Van Dam M | Efficacy of concentrated n-3 fatty acids in hypertriglyceridaemia: A comparison with gemfibrozil | Clinical Drug Investigation | Comparator not different or no n-3
none | D. G. J. W. M. E. B. S. J. H. D. P. N. M. K. J. J. P. Stalenhoef Afh | The effect of concentrated n-3 fatty acids versus gemfibrozil on plasma lipoproteins, low density lipoprotein heterogeneity and oxidizability in patients with hypertrygliceridemia | Atherosclerosis | Comparator not different or no n-3
12499320 | Laidlaw M and Holub BJ | Effects of supplementation with fish oil-derived n-3 fatty acids and gamma-linolenic acid on circulating plasma lipids and fatty acid profiles in women. | The American Journal of Clinical Nutrition | Comparator not different or no n-3
none | P. J. H. S. Jones and V. K.; Pu and S.; Jenkins and D. J. A.; Connelly and P. W.; Lamarche and B.; Couture and P.; Charest and A.; Baril-Gravel and L.; West and S. G.; Liu and X.; Fleming and J. A.; McCrea and C. E.; Kris-Etherton and P. M. | Dha-enriched high-oleic acid canola oil improves lipid profile and lowers predicted cardiovascular disease risk in the canola oil multicenter randomized controlled trial | American Journal of Clinical Nutrition | Duplicate publication, no additional data
none | S. S. Tsugane and N. | The JPHC study: Design and some findings on the typical Japanese diet | Japanese Journal of Clinical Oncology | Duplicate publication, no additional data
none | N. T. Eliana and A.; Dias and F.; Orsatti and C.; Rodrigues and M.; Nahas-Neto and J. | Effect of diet and omega 3 supplementation on the metabolic and inflammatory markers in postmenopausal women with metabolic syndrome: A randomized controlled trial | Climacteric | Duplicate publication, no additional data
24777981 | Caligiuri SP and Aukema HM and Ravandi A and Guzman R and Dibrov E and Pierce GN | Flaxseed consumption reduces blood pressure in patients with hypertension by altering circulating oxylipins via an alpha-linolenic acid-induced inhibition of soluble epoxide hydrolase. | Hypertension | Duplicate publication, no additional data
24529505 | T. M. Hisamatsu and K. Ohkubo and T. Yamamoto and T. Fujiyoshi and A. Miyagawa and N. Kadota and A. Takashima and N. Okuda and N. Yoshita and K. Kita and Y. Murakami and Y. Nakamura and Y. Okamura and T. Horie and M. Okayama and A. Ueshima and H. | High long-chain n-3 fatty acid intake attenuates the effect of high resting heart rate on cardiovascular mortality risk: A 24-year follow-up of Japanese general population | Journal of Cardiology | Duplicate publication, no additional data
23835245 | Brinton EA | Effects of icosapent ethyl on lipid and inflammatory parameters in patients with diabetes mellitus-2, residual elevated triglycerides (200–500 mg/dL), and on statin therapy at LDL-C goal: The ANCHOR study | | Duplicate publication, no additional data
23351824 | Masson S and Marchioli R and Mozaffarian D and Bernasconi R and Milani V and Dragani L and Tacconi M and Marfisi RM and Borgese L and Cirrincione V and Febo O and Nicolis E and Maggioni AP and Tognoni G and Tavazzi L and Latini R | Plasma n-3 polyunsaturated fatty acids in chronic heart failure in the GISSI-Heart Failure Trial: relation with fish intake, circulating biomarkers, and mortality. | American Heart Journal | Duplicate publication, no additional data
23312051 | Derosa G and Cicero AF and Fogari E and D’Angelo A and Bonaventura A and Romano D and Maffioli P | Effects of n-3 PUFAs on postprandial variation of metalloproteinases, and inflammatory and insulin resistance parameters in dyslipidemic patients: evaluation with euglycemic clamp and oral fat load. | Journal of Clinical Lipidology | Duplicate publication, no additional data
22653220 | Itakura H and Yokoyama M and Matsuzaki M and Saito Y and Origasa H and Ishikawa Y and Oikawa S and Sasaki J and Hishida H and Kita T and Kitabatake A and Nakaya N and Sakata T and Shimada K and Shirato K and Matsuzawa Y | The change in low-density lipoprotein cholesterol concentration is positively related to plasma docosahexaenoic acid but not eicosapentaenoic acid. | Journal of Atherosclerosis and Thrombosis | Duplicate publication, no additional data
22186099 | Sasaki J and Yokoyama M and Matsuzaki M and Saito Y and Origasa H and Ishikawa Y and Oikawa S and Itakura H and Hishida H and Kita T and Kitabatake A and Nakaya N and Sakata T and Shimada K and Shirato K and Matsuzawa Y | Relationship between coronary artery disease and non-HDL-C, and effect of highly purified EPA on the risk of coronary artery disease in hypercholesterolemic patients treated with statins: sub-analysis of the Japan EPA Lipid Intervention Study (JELIS). | Journal of Atherosclerosis and Thrombosis | Duplicate publication, no additional data
22110169 | Kromhout D and Geleijnse JM and de Goede J and Oude Griep LM and Mulder BJ and de Boer MJ and Deckers JW and Boersma E and Zock PL and Giltay EJ | n-3 fatty acids, ventricular arrhythmia-related events, and fatal myocardial infarction in postmyocardial infarction patients with diabetes. | Diabetes Care | Duplicate publication, no additional data
21839455 | Paniagua JA and Perez-Martinez P and Gjelstad IM and Tierney AC and Delgado-Lista J and Defoort C and Blaak EE and Riserus U and Drevon CA and Kiec-Wilk B and Lovegrove JA and Roche HM and Lopez-Miranda J | A low-fat high-carbohydrate diet supplemented with long-chain n-3 PUFA reduces the risk of the metabolic syndrome. | Atherosclerosis | Duplicate publication, no additional data
21315217 | Finzi AA and Latini R and Barlera S and Rossi MG and Ruggeri A and Mezzani A and Favero C and Franzosi MG and Serra D and Lucci D and Bianchini F and Bernasconi R and Maggioni AP and Nicolosi G and Porcu M and Tognoni G and Tavazzi L and Marchioli R | Effects of n-3 polyunsaturated fatty acids on malignant ventricular arrhythmias in patients with chronic heart failure and implantable cardioverter-defibrillators: A substudy of the Gruppo Italiano per lo Studio della Sopravvivenza nell’Insufficienza Cardiaca (GISSI-HF) trial. | American Heart Journal | Duplicate publication, no additional data
21036355 | Neil HA and Ceglarek U and Thiery J and Paul S and Farmer A and Holman RR | Impact of atorvastatin and omega-3 ethyl esters 90 on plasma plant sterol concentrations and cholesterol synthesis in type 2 diabetes: a randomised placebo controlled factorial trial. | Atherosclerosis | Duplicate publication, no additional data
20631323 | Jimenez-Gomez Y and Marin C and Peerez-Martinez P and Hartwich J and Malczewska-Malec M and Golabek I and Kiec-Wilk B and Cruz-Teno C and Rodriguez F and Gomez P and Gomez-Luna MJ and Defoort C and Gibney MJ and Perez-Jimenez F and Roche HM and Lopez-Miranda J | A low-fat, high-complex carbohydrate diet supplemented with long-chain (n-3) fatty acids alters the postprandial lipoprotein profile in patients with metabolic syndrome. | The Journal of Nutrition | Duplicate publication, no additional data
20233037 | Hartwich J and Leszczynska-Golabek I and Kiec-Wilk B and Siedlecka D and Perez-Martinez P and Marin C and Lopez-Miranda J and Tierney A and Monagle JM and Roche HM and Defoort C and Wolkow P and Dembinska-Kiec A | Lipoprotein profile, plasma ischemia modified albumin and LDL density change in the course of postprandial lipemia. Insights from the LIPGENE study. | Scandinavian Journal of Clinical and Laboratory Investigation | Duplicate publication, no additional data
20202290 | Gulseth HL and Gjelstad IM and Tierney AC and Shaw DI and Helal O and Hees AM and Delgado-Lista J and Leszczynska-Golabek I and Karlstrom B and Lovegrove J and Defoort C and Blaak EE and Lopez-Miranda J and Dembinska-Kiec A and Riserus U and Roche HM and Birkeland KI and Drevon CA | Dietary fat modifications and blood pressure in subjects with the metabolic syndrome in the LIPGENE dietary intervention study. | The British Journal of Nutrition | Duplicate publication, no additional data
20145342 | Origasa H and Yokoyama M and Matsuzaki M and Saito Y and Matsuzawa Y | Clinical importance of adherence to treatment with eicosapentaenoic acid by patients with hypercholesterolemia. | Circulation Journal : Official Journal of the Japanese Circulation Society | Duplicate publication, no additional data
19481310 | Hartwich J and Malec MM and Partyka L and Perez-Martinez P and Marin C and Lopez-Miranda J and Tierney AC and Mc Monagle J and Roche HM and Defoort C and Wolkow P and Dembinska-Kiec A | The effect of the plasma n-3/n-6 polyunsaturated fatty acid ratio on the dietary LDL phenotype transformation - insights from the LIPGENE study. | Clinical Nutrition (Edinburgh, Scotland) | Duplicate publication, no additional data
19447387 | Oikawa S and Yokoyama M and Origasa H and Matsuzaki M and Matsuzawa Y and Saito Y and Ishikawa Y and Sasaki J and Hishida H and Itakura H and Kita T and Kitabatake A and Nakaya N and Sakata T and Shimada K and Shirato K | Suppressive effect of EPA on the incidence of coronary events in hypercholesterolemia with impaired glucose metabolism: Sub-analysis of the Japan EPA Lipid Intervention Study (JELIS). | Atherosclerosis | Duplicate publication, no additional data
19423946 | Matsuzaki M and Yokoyama M and Saito Y and Origasa H and Ishikawa Y and Oikawa S and Sasaki J and Hishida H and Itakura H and Kita T and Kitabatake A and Nakaya N and Sakata T and Shimada K and Shirato K and Matsuzawa Y | Incremental effects of eicosapentaenoic acid on cardiovascular events in statin-treated patients with coronary artery disease. | Circulation Journal : Official Journal of the Japanese Circulation Society | Duplicate publication, no additional data
18667204 | Saito Y and Yokoyama M and Origasa H and Matsuzaki M and Matsuzawa Y and Ishikawa Y and Oikawa S and Sasaki J and Hishida H and Itakura H and Kita T and Kitabatake A and Nakaya N and Sakata T and Shimada K and Shirato K | Effects of EPA on coronary artery disease in hypercholesterolemic patients with multiple risk factors: sub-analysis of primary prevention cases from the Japan EPA Lipid Intervention Study (JELIS). | Atherosclerosis | Duplicate publication, no additional data
18544171 | P. B. Galan and S. Blacher and J. Czernichow and S. Hercberg and S. | The SU.FOL.OM3 Study: A secondary prevention trial testing the impact of supplementation with folate and B-vitamins and/or Omega-3 PUFA on fatal and non fatal cardiovascular events, design, methods and participants characteristics | Trials | Duplicate publication, no additional data
17934973 | Furenes EB and Seljeflot I and Solheim S and Hjerkinn EM and Arnesen H | Long-term influence of diet and/or omega-3 fatty acids on matrix metalloproteinase-9 and pregnancy-associated plasma protein-A in men at high risk of coronary heart disease. | Scandinavian Journal of Clinical and Laboratory Investigation | Duplicate publication, no additional data
17327141 | Lindi V and Schwab U and Louheranta A and Vessby B and Hermansen K and Tapsell L and Riccardi G and Rivellese AA and Laakso M and Uusitupa MI | The G-250A polymorphism in the hepatic lipase gene promoter is associated with changes in hepatic lipase activity and LDL cholesterol: The KANWU Study. | Nutrition, Metabolism, and Cardiovascular Diseases : NMCD | Duplicate publication, no additional data
16087142 | A. L. Macchia and G. Franzosi and M. G. Geraci and E. Maggioni and A. P. Marfisi and R. Nicolosi and G. L. Schweiger and C. Tavazzi and L. Tognoni and G. Valagussa and F. Marchioli and R. | Left ventricular systolic dysfunction, total mortality, and sudden death in patients with myocardial infarction treated with n-3 polyunsaturated fatty acids | European Journal of Heart Failure | Duplicate publication, no additional data
15175795 | Lindman AS and Pedersen JI and Hjerkinn EM and Arnesen H and Veierod MB and Ellingsen I and Seljeflot I | The effects of long-term diet and omega-3 fatty acid supplementation on coagulation factor VII and serum phospholipids with special emphasis on the R353Q polymorphism of the FVII gene. | Thrombosis and Haemostasis | Duplicate publication, no additional data
12618280 | Rivellese AA and Maffettone A and Vessby B and Uusitupa M and Hermansen K and Berglund L and Louheranta A and Meyer BJ and Riccardi G | Effects of dietary saturated, monounsaturated and n-3 fatty acids on fasting lipoproteins, LDL size and postprandial lipid metabolism in healthy subjects. | Atherosclerosis | Duplicate publication, no additional data
11317662 | Vessby B and Uusitupa M and Hermansen K and Riccardi G and Rivellese AA and Tapsell LC and Nalsen C and Berglund L and Louheranta A and Rasmussen BM and Calvert GD and Maffetone A and Pedersen E and Gustafsson IB and Storlien LH | Substituting dietary saturated for monounsaturated fat impairs insulin sensitivity in healthy men and women: The KANWU Study. | Diabetologia | Duplicate publication, no additional data
10232627 | Hu FB1, Stampfer MJ, Manson JE, Rimm EB, Wolk A, Colditz GA, Hennekens CH, Willett WC. | Dietary intake of alpha-linolenic acid and risk of fatal ischemic heart disease among women. | Am J Clin Nutr. | Duplicate publication, no additional data
9022561 | Whelton PK, Kumanyika SK, Cook NR, Cutler JA, Borhani NO, Hennekens CH, Kuller LH, Langford H, Jones DW, Satterfield S, Lasser NL, Cohen JD. | Efficacy of nonpharmacologic interventions in adults with high-normal blood pressure: results from phase 1 of the Trials of Hypertension Prevention. Trials of Hypertension Prevention Collaborative Research Group. | Am J Clin Nutr. 1997 Feb;65(2 Suppl):652S– 660S. | Duplicate publication, no additional data
7702027 | Eritsland J., Arnesen H., Seljeflot I., Høstmark AT. | Long-term metabolic effects of n-3 polyunsaturated fatty acids in patients with coronary artery disease. | The American Journal of Clinical Nutrition, 1995;61– 4 | Duplicate publication, no additional data
20181806 | Chan DC and Nguyen MN and Watts GF and Ooi EM and Barrett PH | Effects of atorvastatin and n-3 fatty acid supplementation on VLDL apolipoprotein C-III kinetics in men with abdominal obesity. | The American Journal of Clinical Nutrition | Factorial N<30 n-3 arms
16825679 | Chan DC and Watts GF and Nguyen MN and Barrett PH | Factorial study of the effect of n-3 fatty acid supplementation and atorvastatin on the kinetics of HDL apolipoproteins A-I and A-II in men with abdominal obesity. | The American Journal of Clinical Nutrition | Factorial N<30 n-3 arms
12059988 | Chan DC and Watts GF and Mori TA and Barrett PH and Beilin LJ and Redgrave TG | Factorial study of the effects of atorvastatin and fish oil on dyslipidaemia in visceral obesity. | European Journal of Clinical Investigation | Factorial N<30 n-3 arms
18403189 | Yusof HM and Miles EA and Calder P | Influence of very long-chain n-3 fatty acids on plasma markers of inflammation in middle-aged men. | Prostaglandins, Leukotrienes, and Essential Fatty Acids | N<10
8349330 | Vandongen R1, Mori TA, Burke V, Beilin LJ, Morris J, Ritchie J. | Effects on blood pressure of omega 3 fats in subjects at increased risk of cardiovascular disease. | Hypertension. | N<30/arm
24710321 | L. K. Fezeu and Laporte and F. and Kesse-Guyot and E. and Andreeva and V. A. and Blacher and J. and Hercberg and S. and Galan and P. | Baseline plasma fatty acids profile and incident cardiovascular events in the SU.FOL.OM3 trial: the evidence revisited | | No analysis/com parison of interest
24401815 | AlSaleh A and Maniou Z and Lewis FJ and Hall WL and Sanders TA and O’Dell SD | Interaction between a CSK gene variant and fish oil intake influences blood pressure in healthy adults. | The Journal of Nutrition | No analysis/com parison of interest
20410091 | G. Pocobelli and Kristal and A. R. and Patterson and R. E. and Potter and J. D. and Lampe and J. W. and Kolar and A. and Evans and I. and White and E. | Total mortality risk in relation to use of less-common dietary supplements | | No n-3 dose data
17027436 | Moore CS and Bryant SP and Mishra GD and Krebs JD and Browning LM and Miller GJ and Jebb SA | Oily fish reduces plasma triacylglycerols: a primary prevention study in overweight men and women. | Nutrition (Burbank, Los Angeles County, Calif.) | No n-3 dose data
11507963 | Egeland GM, Meyer HE, Selmer R, Tverdal A, Vollset SE. | Cod liver oil consumption, smoking, and coronary heart disease mortality: three counties, Norway. | Int J Circumpolar Health. 2001 Apr;60(2):143–9. | No n-3 dose data
11507963 | G. M. M. Egeland and H. E. Selmer and R. Tverdal and A. Vollset and S. E. | Cod liver oil consumption, smoking, and coronary heart disease mortality: three counties, Norway | International Journal of Circumpolar Health | No n-3 dose
none | C. M. B. Ballantyne and H.; Braeckman and R.; Philip and S.; Stirtan and W.; Doyle and R.; Soni and P. N.; Juliano and R. A. | Icosapent ethyl (eicosapentaenoic acid ethyl ester): Effects on remnant-like particle cholesterol from the marine and anchor studies | Circulation | No outcome of interest
none | A. B. Anullkesson and C.; Bergkvist and M.; Glynn and A.; Julin and B.; Wolk and A. | Dietary exposure to polychlorinated biphenyls and incidence of myocardial infarction in men-a population-based prospective cohort study | Circulation | No outcome of interest
25733777 | K. S. Laake and I.; Fagerland and M. W.; Njerve and I. U.; Arnesen and H.; Solheim and S. | Effects on serum fractalkine by diet and omega-3 fatty acid intervention: Relation to clinical outcome | Mediators of Inflammation | No outcome of interest
24952576 | M. Laidlaw and Cockerline and C. A. and Rowe and W. J. | A randomized clinical trial to determine the efficacy of manufacturers’ recommended doses of omega-3 fatty acids from different sources in facilitating cardiovascular disease risk reduction | | No outcome of interest
24378016 | L. L. M. H. W. S. S. G. C. B. R. C. Augustine Ah | Treatment with omega-3 fatty acid ethyl-ester alters fatty acid composition of lipoproteins in overweight or obese adults with insulin resistance | Prostaglandins, Leukotrienes, and Essential Fatty Acids | No outcome of interest
24063767 | Walker CG and Browning LM and Mander AP and Madden J and West AL and Calder PC and Jebb SA | Age and sex differences in the incorporation of EPA and DHA into plasma fractions, cells and adipose tissue in humans. | The British Journal of Nutrition | No outcome of interest
23885702 | Lemke SL and Maki KC and Hughes G and Taylor ML and Krul ES and Goldstein DA and Su H and Rains TM and Mukherjea R | Consumption of stearidonic acid-rich oil in foods increases red blood cell eicosapentaenoic acid. | Journal of the Academy of Nutrition and Dietetics | No outcome of interest
23756586 | Katz DL and Davidhi A and Ma Y and Kavak Y and Bifulco L and Njike VY | Effects of walnuts on endothelial function in overweight adults with visceral obesity: a randomized, controlled, crossover trial. | Journal of the American College of Nutrition | No outcome of interest
23325450 | Bays HE and Ballantyne CM and Braeckman RA and Stirtan WG and Soni PN | Icosapent ethyl, a pure ethyl ester of eicosapentaenoic acid: effects on circulating markers of inflammation from the MARINE and ANCHOR studies. | American Journal of Cardiovascular Drugs : Drugs, Devices, and other Interventions | No outcome of interest
23179200 | Zong G and Demark-Wahnefried W and Wu H and Lin X | Effects of flaxseed supplementation on erythrocyte fatty acids and multiple cardiometabolic biomarkers among Chinese with risk factors of metabolic syndrome. | European Journal of Nutrition | No outcome of interest
22661243 | Crochemore IC and Souza AF and de Souza AC and Rosado EL | omega-3 polyunsaturated fatty acid supplementation does not influence body composition, insulin resistance, and lipemia in women with type 2 diabetes and obesity. | Nutrition in Clinical Practice : Official Publication of the American Society for Parenteral and Enteral Nutrition | No outcome of interest
22108152 | Maki KC and Bays HE and Dicklin MR and Johnson SL and Shabbout M | Effects of prescription omega-3-acid ethyl esters, coadministered with atorvastatin, on circulating levels of lipoprotein particles, apolipoprotein CIII, and lipoprotein-associated phospholipase A2 mass in men and women with mixed dyslipidemia. | Journal of Clinical Lipidology | No outcome of interest
21624541 | Kumar S and Sutherland F and Teh AW and Heck PM and Lee G and Garg ML and Sparks PB | Effects of chronic omega-3 polyunsaturated fatty acid supplementation on human pulmonary vein and left atrial electrophysiology in paroxysmal atrial fibrillation. | The American Journal of Cardiology | No outcome of interest
20394870 | Gajos G1, Rostoff P, Undas A, Piwowarska W. | Effects of polyunsaturated omega-3 fatty acids on responsiveness to dual antiplatelet therapy in patients undergoing percutaneous coronary intervention: the OMEGA-PCI (OMEGA-3 fatty acids after pci to modify responsiveness to dual antiplatelet therapy) study. | J Am Coll Cardiol. | No outcome of interest
19843899 | Carney RM1, Freedland KE, Rubin EH, Rich MW, Steinmeyer BC, Harris WS. | Omega-3 augmentation of sertraline in treatment of depression in patients with coronary heart disease: a randomized controlled trial. | JAMA | No outcome of interest
19158225 | Kelley DS and Siegel D and Fedor DM and Adkins Y and Mackey BE | DHA supplementation decreases serum C-reactive protein and other markers of inflammation in hypertriglyceridemic men. | The Journal of Nutrition | No outcome of interest
19133114 | Valdivielso P and Rioja J and Garcia-Arias C and Sanchez-Chaparro MA and Gonzalez-Santos P | Omega 3 fatty acids induce a marked reduction of apolipoprotein B48 when added to fluvastatin in patients with type 2 diabetes and mixed hyperlipidemia: a preliminary report. | Cardiovascular Diabetology | No outcome of interest
18689552 | Austria JA and Richard MN and Chahine MN and Edel AL and Malcolmson LJ and Dupasquier CM and Pierce GN | Bioavailability of alpha-linolenic acid in subjects after ingestion of three different forms of flaxseed. | Journal of the American College of Nutrition | No outcome of interest
18156400 | Kelley DS and Siegel D and Vemuri M and Chung GH and Mackey BE | Docosahexaenoic acid supplementation decreases remnant-like particle-cholesterol and increases the (n-3) index in hypertriglyceridemic men. | The Journal of Nutrition | No outcome of interest
17179018 | Steffen LM1, Folsom AR, Cushman M, Jacobs DR Jr, Rosamond WD. | Greater fish, fruit, and vegetable intakes are related to lower incidence of venous thromboembolism: the Longitudinal Investigation of Thromboembolism Etiology. | Circulation. | No outcome of interest
15262190 | Mesa MD and Buckley R and Minihane AM and Yaqoob P | Effects of oils rich in eicosapentaenoic and docosahexaenoic acids on the oxidizability and thrombogenicity of low-density lipoprotein. | Atherosclerosis | No outcome of interest
15208005 | Harris WS and Von Schacky C | The Omega-3 Index: a new risk factor for death from coronary heart disease? | Preventive Medicine | No outcome of interest
12771973 | Pedersen H and Petersen M and Major-Pedersen A and Jensen T and Nielsen NS and Lauridsen ST and Marckmann P | Influence of fish oil supplementation on in vivo and in vitro oxidation resistance of low-density lipoprotein in type 2 diabetes. | European Journal of Clinical Nutrition | No outcome of interest
12075272 | Maresta A., Balduccelli M., Varani E., Marzilli M., Galli C., Heiman F., Lavezzari M., Stragliotto E., De Caterina R. | Prevention of postcoronary angioplasty restenosis by omega-3 fatty acids: main results of the Esapent for Prevention of Restenosis ITalian Study (ESPRIT). | American Heart Journal; 2002, 143–6 | No outcome of interest
12062374 | Angerer P., Kothny W., Störk S., von Schacky C. | Effect of dietary supplementation with omega-3 fatty acids on progression of atherosclerosis in carotid arteries. | Cardiovascular Research, 2002, 54-1 | No outcome of interest
8688759 | Ascherio A1, Rimm EB, Giovannucci EL, Spiegelman D, Stampfer M, Willett WC. | Dietary fat and risk of coronary heart disease in men: cohort follow up study in the United States. | BMJ. | No outcome of interest
8540453 | Eritsland J1, Arnesen H, Grønseth K, Fjeld NB, Abdelnoor M. | Effect of dietary supplementation with n-3 fatty acids on coronary artery bypass graft patency. | Am J Cardiol. | No outcome of interest
8462079 | Franzen, 1993 | A prospective, randomized, and double-blind trial on the effect of fish oil on the incidence of restenosis following PTCA. | Cathet Cardiovasc Diagn. 1993 Apr;28(4):301–10. | No outcome of interest
7955181 | Leaf A1, Jorgensen MB, Jacobs AK, Cote G, Schoenfeld DA, Scheer J, Weiner BH, Slack JD, Kellett MA, Raizner AE, et al. | Do fish oils prevent restenosis after coronary angioplasty? | Circulation. | No outcome of interest
6320945 | Woodcock BE, Smith E, Lambert WH, Jones WM, Galloway JH, Greaves M, Preston FE. | Beneficial effect of fish oil on blood viscosity in peripheral vascular disease. | Br Med J (Clin Res Ed). | No outcome of interest
2842680 | Dehmer GJ1, Popma JJ, van den Berg EK, Eichhorn EJ, Prewitt JB, Campbell WB, Jennings L, Willerson JT, Schmitz JM. | Reduction in the rate of early restenosis after coronary angioplasty by a diet supplemented with n-3 fatty acids | N Engl J Med. | No outcome of interest
2842680 | Dehmer GJ1, Popma JJ, van den Berg EK, Eichhorn EJ, Prewitt JB, Campbell WB, Jennings L, Willerson JT, Schmitz JM. | Reduction in the rate of early restenosis after coronary angioplasty by a diet supplemented with n-3 fatty acids. | N Engl J Med. | No outcome of interest
2568519 | Reis GJ1, Boucher TM, Sipperly ME, Silverman DI, McCabe CH, Baim DS, Sacks FM, Grossman W, Pasternak RC. | Randomised trial of fish oil for prevention of restenosis after coronary angioplasty. | Lancet. | No outcome of interest
2526993 | Milner MR1, Gallino RA, Leffingwell A, Pichard AD, Brooks-Robinson S, Rosenberg J, Little T, Lindsay J Jr. | Usefulness of fish oil supplements in preventing clinical evidence of restenosis after percutaneous transluminal coronary angioplasty. | Am J Cardiol. | No outcome of interest
1902298 | Singer P., Wirth M., Kretschmer H. | Different changes of n-6 fatty acids in lipoproteins from hyperlipemic subjects after diets supplemented with n-3 fatty acids. | Prostaglandins Leukot Essent Fatty Acids. 1991 Feb;42(2):107–11. | No outcome of interest
1537131 | Bairati I1, Roy L, Meyer F. | Double-blind, randomized, controlled trial of fish oil supplements in prevention of recurrence of stenosis after coronary angioplasty. | Circulation. | No outcome of interest
1289091 | Bellamy CM1, Schofield PM, Faragher EB, Ramsdale DR. | Can supplementation of diet with omega-3 polyunsaturated fatty acids reduce coronary angioplasty restenosis rate? | Eur Heart J. | No outcome of interest
none | G. Colussi and Catena and C. and Dialti and V. and Pezzutto and F. and Mos and L. and Sechi and L. A. | Fish meal supplementation and ambulatory blood pressure in patients with hypertension: relevance of baseline membrane fatty acid composition | | Non-comparative
20156032 | Bays HE and Maki KC and McKenney J and Snipes R and Meadowcroft A and Schroyer R and Doyle RT and Stein E | Long-term up to 24-month efficacy and safety of concomitant prescription omega-3-acid ethyl esters and simvastatin in hypertriglyceridemic patients. | Current Medical Research and Opinion | Non-comparative
19584895 | Patenaude A and Rodriguez-Leyva D and Edel AL and Dibrov E and Dupasquier CM and Austria JA and Richard MN and Chahine MN and Malcolmson LJ and Pierce GN | Bioavailability of alpha-linolenic acid from flaxseed diets as a function of the age of the subject. | European Journal of Clinical Nutrition | Non-comparative
19364085 | De Luis DA and Conde R and Aller R and Izaola O and Gonzalez Sagrado M and Perez Castrillon JL and Duenas A and Romero E | Effect of omega-3 fatty acids on cardiovascular risk factors in patients with type 2 diabetes mellitus and hypertriglyceridemia: an open study. | European Review for Medical and Pharmacological Sciences | Non-comparative
18525453 | Vega GL and Chandalia M and Szczepaniak LS and Grundy SM | Effects of N-3 fatty acids on hepatic triglyceride content in humans. | Journal of Investigative Medicine : The Official Publication of the American Federation for Clinical Research | Non-comparative
18242615 | Elvevoll EO and Eilertsen KE and Brox J and Dragnes BT and Falkenberg P and Olsen JO and Kirkhus B and Lamglait A and Osterud B | Seafood diets: hypolipidemic and antiatherogenic effects of taurine and n-3 fatty acids. | Atherosclerosis | Non-comparative
17461697 | Burns T and Maciejewski SR and Hamilton WR and Zheng M and Mooss AN and Hilleman DE | Effect of omega-3 fatty acid supplementation on the arachidonic acid:eicosapentaenoic acid ratio. | Pharmacotherapy | Non-comparative
15173404 | Surette ME and Edens M and Chilton FH and Tramposch KM | Dietary echium oil increases plasma and neutrophil long-chain (n-3) fatty acids and lowers serum triacylglycerols in hypertriglyceridemic humans. | The Journal of Nutrition | Non-comparative
14639803 | Nestares T and Lopez-Jurado M and Urbano G and Seiquer I and Ramirez-Tortosa MC and Ros E and Mataix J and Gil A | Effects of lifestyle modification and lipid intake variations on patients with peripheral vascular disease. | International Journal for Vitamin and Nutrition Research. Internationale Zeitschrift fur Vitamin- und Ernahrungsforschung. Journal International de Vitaminologie et de Nutrition | Non-comparative
11938024 | Kesavulu MM and Kameswararao B and Apparao Ch and Kumar EG and Harinarayan CV | Effect of omega-3 fatty acids on lipid peroxidation and antioxidant enzyme status in type 2 diabetic patients. | Diabetes & Metabolism | Non-comparative
none | J. M. Yuan | Seafood and myocardial infarction in China | | Not available
11494668 | Meshcheriakova VA, Plotnikova OA, Sharafetdinov KhKh, Alekseeva RI, Mal’tsev GIu, Kulakova SN. | Comparative study of effects of diet therapy including eiconol or linseed oil on several parameters of lipid metabolism in patients with type 2 diabetes mellitus. | Vopr Pitan. | Not in English
11247166 | Alekseeva RI, Sharafetdinov KhKh, Plotnikova OA, Meshcheriakova VA, Mal’tsev GIu, Kulakova SN. | Effects of diet therapy including eiconol on clinical and metabolic parameters in patients with type 2 diabetes mellitus. | Vopr Pitan. | Not in English
none | M. I. Gautam and A.; Shiba and Y.; Motoki and H.; Takeuchi and T.; Okada and A.; Tomita and T.; Miyashita and Y.; Koyama and J.; Ikeda and U. | Importance of fatty acid compositions in patients with peripheral arterial disease | PLoS ONE | Not longitudinal
none | K. M. B. Smith and L. M. Kantor and M. Sahyoun and N. R. | Relationship between fish intake, n-3 fatty acids, mercury and risk markers of CHD (National Health and Nutrition Examination Survey 1999–2002) | Public Health Nutrition | Not longitudinal
18579573 | Turunen AW and Verkasalo PK and Kiviranta H and Pukkala E and Jula A and Mannisto S and Rasanen R and Marniemi J and Vartiainen T | Mortality in a cohort with high fish consumption. | International Journal of Epidemiology | Not longitudinal
11684529 | Djoussé L, Pankow JS, Eckfeldt JH, Folsom AR, Hopkins PN, Province MA, Hong Y, Ellison RC. | Relation between dietary linolenic acid and coronary artery disease in the National Heart, Lung, and Blood Institute Family Heart Study. | Am J Clin Nutr. 2001 Nov;74(5):612–9. | Not longitudinal
1350705 | Bonaa, 1992 | Habitual fish consumption, plasma phospholipid fatty acids, and serum lipids: the Tromsø study | Am J Clin Nutr. 1992 Jun;55(6):1126–34. | Not longitudinal
none | P. H. Wurtz and A. S.; Soininen and P.; Tynkkynen and T.; Prieto-Merino and D.; Tillin and T.; Ghorbani and A.; Artati and A.; Wang and Q.; Tiainen and M.; Kangas and A. J.; Kettunen and J.; Kaikkonen and J.; Mikkila and V.; Jula and A.; Kahonen and M.; Lehtimaki and T.; Lawlor and D. A.; Gaunt and T. R.; Hughes and A. D.; Sattar and N.; Illig and T.; Adamski and J.; Wang and T. J.; Perola and M.; Ripatti and S.; Vasan and R. S.; Raitakari and O. T.; Gerszten and R. E.; Casas and J. P.; Chaturvedi and N.; Ala-Korpela and M.; Salomaa and V. | Metabolite profiling and cardiovascular event risk: A prospective study of 3 population-based cohorts | Circulation | Not primary study
none | A. M. Farmer and V. Dinneen and S. Clar and C. | Fish oil in people with type 2 diabetes mellitus | Cochrane Database of Systematic Reviews (Online) | Not primary study
none | F. D. Campbell and H. O. Critchley and J. A. Ford and G. A. Bradburn and M. | A systematic review of fish-oil supplements for the prevention and treatment of hypertension | European Journal of Preventive Cardiology | Not primary study
none | H. S. Leon and M. C. Sivakumaran and S. Dorgan and M. Chatterley and T. Tsuyuki and R. T. | Effect of fish oil on arrhythmias and mortality: systematic review | BMJ (Clinical researched.) | Not primary study
none | Y. Li and Zhou and ChengHui and Pei and HanJun and Zhou and XianLiang and Li and LiHuan and Wu and YongJian and Hui and RuTai | Fish consumption and incidence of heart failure: a meta-analysis of prospective cohort studies | | Not primary study
none | Y. Momiyama | Association between serum omega-3 to omega-6 polyunsaturated fatty acid ratio and cardiovascular events in a general Japanese population | Atherosclerosis | Not primary study
none | D. d. G. Kromhout and J.; Kromhout and Daan; de Goede and Janette | Update on cardiometabolic health effects of omega-3 fatty acids | Current Opinion in Lipidology | Not primary study
none | L. Gao and Cao and Jian and Mao and QunXia and Lu and XueChun and Zhou and XianLiang and Fan and Li | Influence of omega-3 polyunsaturated fatty acid-supplementation on platelet aggregation in humans: a meta-analysis of randomized controlled trials | | Not primary study
none | W. Xin and Wei and Wei and Lin and ZhiQin and Zhang and XiaoXia and Yang and HongXia and Zhang and Tao and Li and Bin and Mi and ShuHua | Fish oil and atrial fibrillation after cardiac surgery: a meta-analysis of randomized controlled trials | | Not primary study
none | E. C. N. Rizos and E. E. | (omega)-3 fatty acids and lutein+zeaxanthin supplementation for the prevention of cardiovascular disease | JAMA Internal Medicine | Not primary study
none | S. I. Khalesi and C.; Schubert and M. | Flaxseed consumption may reduce blood pressure: A systematic review and meta-analysis of controlled trials | Journal of Nutrition | Not primary study
none | L. H. Schwingshackl and G. | Dietary fatty acids in the secondary prevention of coronary heart disease: A systematic review, meta-analysis and meta-regression | BMJ Open | Not primary study
none | X. Y. Y. Guo and X. L.; Chen and Y. W.; Tang and R. B.; Du and X.; Dong and J. Z.; Ma and C. S.; Guo and Xue-Yuan; Yan and Xian-Liang; Chen and Ying-Wei; Tang and Ri-Bo; Du and Xin; Dong and Jian-Zeng; Ma and Chang-Sheng | Omega-3 fatty acids for postoperative atrial fibrillation: alone or in combination with antioxidant vitamins? | Heart, Lung & Circulation | Not primary study
none | J. E. Y. Enns and A.; Zarychanski and R.; Abou-Setta and A. M.; Friesen and C.; Zahradka and P.; Taylor and C. G.; Enns and Jennifer E.; Yeganeh and Azadeh; Zarychanski and Ryan; Abou-Setta and Ahmed M.; Friesen and Carol; Zahradka and Peter; Taylor and Carla G. | The impact of omega-3 polyunsaturated fatty acid supplementation on the incidence of cardiovascular events and complications in peripheral arterial disease: a systematic review and meta-analysis | BMC Cardiovascular Disorders | Not primary study
none | T. Z. Zheng and J.; Wang and Y.; Liu and W.; Wang and Z.; Shang and Y.; Zhang and W.; Zhang and Y.; Zhong and M. | The limited effect of omega-3 polyunsaturated fatty acids on cardiovascular risk in patients with impaired glucose metabolism: A meta-analysis | Clinical Biochemistry | Not primary study
none | P. Calder | Limited impact of omega-3 fatty acids in patients with multiple cardiovascular risk factors | Evidence-Based Medicine | Not primary study
none | Z. Kmietowicz | Omega 3 supplements do not reduce cardiovascular risk in elderly | BMJ (Online) | Not primary study
none | P. E. V. E. Miller and M.; Alexander and D. D. | Long-chain Omega-3 fatty acids eicosapentaenoic acid and docosahexaenoic acid and blood pressure: A meta-analysis of randomized controlled trials | American Journal of Hypertension | Not primary study
none | R. W. Chowdhury and S.; Kunutsor and S.; Crowe and F.; Ward and H. A.; Johnson and L.; Franco and O. H.; Butterworth and A. S.; Forouhi and N. G.; Thompson and S. G.; Khaw and K. T.; Mozaffarian and D.; Danesh and J.; Di Angelantonio and E. | Association of dietary, circulating, and supplement fatty acids with coronary risk: A systematic review and meta-analysis | Annals of Internal Medicine | Not primary study
none | Y. T. D. Wen and J. H.; Gao and Q. | Effects of Omega-3 fatty acid on major cardiovascular events and mortality in patients with coronary heart disease: a meta-analysis of randomized controlled trials | Nutrition Metabolism & Cardiovascular Diseases | Not primary study
22011460 | Danthiir V and Burns NR and Nettelbeck T and Wilson C and Wittert G | The older people, omega-3, and cognitive health (EPOCH) trial design and methodology: a randomised, double-blind, controlled trial investigating the effect of long-chain omega-3 fatty acids on cognitive ageing and wellbeing in cognitively healthy older adults. | Nutrition JJournal | Not primary study
18082485 | Gerstein H and Yusuf S and Riddle MC and Ryden L and Bosch J | Rationale, design, and baseline characteristics for a large international trial of cardiovascular disease prevention in people with dysglycemia: the ORIGIN Trial (Outcome Reduction with an Initial Glargine Intervention). | American HHeart JJournal | Not primary study
17124558 | Rauch B and Schiele R and Schneider S and Gohlke H and Diller F and Gottwik M and Steinbeck G and Heer T and Katus H and Zimmer R and Erdogan A and Pfafferott C and Senges J | Highly purified omega-3 fatty acids for secondary prevention of sudden cardiac death after myocardial infarction-aims and methods of the OMEGA-study. | Cardiovascular Drugs and Therapy / Sponsored by the International Society of Cardiovascular Pharmacotherapy | Not primary study
11837985 | Marchioli R and Schweiger C and Tavazzi L and Valagussa F | Efficacy of n-3 polyunsaturated fatty acids after myocardial infarction: results of GISSI-Prevenzione trial. Gruppo Italiano per lo Studio della Sopravvivenza nell’Infarto Miocardico. | Lipids | Not primary study
2053348 | Singer P, Hueve J. | Blood pressure-lowering effect of fish oil, propranolol and the combination of both in mildly hypertensive patients | World Rev Diet 1991;66:522–3. | Not primary study
none | T. K. Teramoto and R.; Miyazaki and S.; Teramukai and S.; Sato and Y.; Okuda and Y.; Shirayama and M. | Lipid and Blood Pressure Control for the Prevention of Cardiovascular Disease in Hypertensive Patients: A Subanalysis of the OMEGA Study | Journal of Atherosclerosis and Thrombosis | Not specifically n-3 intervention/exposure
none | M. R. K. Mahmoodi and M.; Mehrabi and Y. | The effects of omega-3 plus vitamin E and zinc plus vitamin C supplementation on cardiovascular risk markers in postmenopausal women with type 2 diabetes | Therapeutic Advances in Endocrinology and Metabolism | Not specifically n-3 intervention/exposure
none | K. R. Tuttle and Shuler and L. A. and Packard and D. P. and Milton and J. E. and Daratha and K. B. and Bibus and D. M. and Short and R. A. | Comparison of low-fat versus Mediterranean-style dietary intervention after first myocardial infarction (from the Heart Institute of Spokane Diet Intervention and Evaluation Trial) | | Not specifically n-3 intervention/exposure
none | C. d. Natale and Minerva and V. and Patti and L. and Mazzarella and R. and Ciano and O. and Maione and S. and Luongo and D. and Naviglio and D. and Marotta and G. and Turco and S. and Ciati and R. and Melegari and C. and Rivellese and A. A. and Riccardi and G. | Effects of baked products enriched with n-3 fatty acids, folates, beta -glucans, and tocopherol in patients with mild mixed hyperlipidemia | | Not specifically n-3 intervention/exposure
none | E. R. S.-S. J. M.-G. M. A. A. F. V. J. C. D. D. O. S. G. D. L. T. R. M. Fito M | Effect of the Mediterranean diet on heart failure biomarkers: A randomized sample from the PREDIMED trial | European Journal of Heart Failure | Not specifically n-3 intervention/exposure
none | F. Tsofliou and Fyfe and C. L. and Matheson and I. and Jackson and D. M. and Horgan and G. W. and Wahle and K. W. J. and Ahren and B. and Williams and L. M. and Sneddon and A. A. | Modulation of fasted and postprandial plasma lipids in healthy volunteers by a dietary mixture of omega-3 fatty acids and conjugated linoleic acid | | Not specifically n-3 intervention/exposure
none | F. Y. Moloney and T. P. Mullen and A. Nolan and J. J. Roche and H. M. | Conjugated linoleic acid supplementation, insulin sensitivity, and lipoprotein metabolism in patients with type 2 diabetes mellitus | American Journal of Clinical Nutrition | Not specifically n-3 intervention/exposure
none | Avellone G. and Guarnotta and V. and Garbo and V. di and Abruzzese and G. and Campisi and D. and Pinto and A. and Pizzo and G. and Licata and G. | Impact of atorvastatin plus n-3 PUFA on metabolic, inflammatory and coagulative parameters in metabolic syndrome without and with type 2 diabetes mellitus | International Journal of Medicine | Not specifically n-3 intervention/exposure
none | J. Tovar and Nilsson and A. and Johansson and M. and Ekesbo and R. and Aberg and A. M. and Johansson and U. and Bjorck and I. | A diet based on multiple functional concepts improves cardiometabolic risk parameters in healthy subjects | | Not specifically n-3 intervention/exposure
none | O. A. P. Tokede and A. B. Hanson and N. Q. Tsai and M. Y. Weir and N. A. Glynn and R. J. Gaziano and J. M. Djousse and L. | Plasma phospholipid trans fatty acids and risk of heart failure | American Journal of Clinical Nutrition | Not specifically n-3 intervention/exposure
none | R. Casas and Sacanella and E. and Urpi-Sarda and M. and Chiva-Blanch and G. and Ros and E. and Martinez-Gonzalez and M. A. and Covas and M. I. and Lamuela-Raventos and R. M. and Salas-Salvado and J. and Fiol and M. and Aros and F. and Estruch and R. | The effects of the Mediterranean diet on biomarkers of vascular wall inflammation and plaque vulnerability in subjects with high risk for cardiovascular disease. A randomized trial | | Not specifically n-3 intervention/exposure
none | R. N. K. Lemaitre and I. B. Mozaffarian and D. Sotoodehnia and N. Rea and T. D. Kuller and L. H. Tracy and R. P. Siscovick and D. S. | Plasma phospholipid trans fatty acids, fatal ischemic heart disease, and sudden cardiac death in older adults: The cardiovascular health study | Circulation | Not specifically n-3 intervention/exposure
none | N. R. O. Matthan and E. M.; Horn and L. V.; Neuhouser and M. L.; Woodman and R.; Lichtenstein and A. H. | Plasma phospholipid fatty acid biomarkers of dietary fat quality and endogenous metabolism predict coronary heart disease risk: A nested case-control study within the women’s health initiative observational study | Journal of the American Heart Association | Not specifically n-3 intervention/exposure
none | S. E. S. Chiuve and R. K.; Moorthy and M. V.; Glynn and R. J.; Albert and C. M. | Dietary fatty acids and risk of incident atrial fibrillation in the women’s health study | Circulation | not specifically n-3 intervention/exposure
no | Silvis, N.; Vorster, H. H.; Mollentze, W. F.; Jagar, J. de; Huisman, H. W. | Metabolic and haemostatic consequences of dietary fibre and N-3 fatty acids in black type 2 (NIDDM) diabetic subjects: a placebo controlled study. | International Clinical Nutrition Review | Not specifically n-3 intervention/exposure
24714723 | Eshak ES and Iso H and Yamagishi K and Kokubo Y and Saito I and Yatsuya H and Sawada N and Inoue M and Tsugane S | Modification of the excess risk of coronary heart disease due to smoking by seafood/fish intake. | American Journal of Epidemiology | Not specifically n-3 intervention/exposure
24360749 | Wu L and Piotrowski K and Rau T and Waldmann E and Broedl UC and Demmelmair H and Koletzko B and Stark RG and Nagel JM and Mantzoros CS and Parhofer KG | Walnut-enriched diet reduces fasting non-HDL-cholesterol and apolipoprotein B in healthy Caucasian subjects: a randomized controlled cross-over clinical trial. | Metabolism: Clinical and Experimental | Not specifically n-3 intervention/exposure
23813701 | Lajous M and Willett WC and Robins J and Young JG and Rimm E and Mozaffarian D and Hernan MA | Changes in fish consumption in midlife and the risk of coronary heart disease in men and women. | American Journal of Epidemiology | Not specifically n-3 intervention/exposure
23487436 | Imamura F and Lemaitre RN and King IB and Song X and Steffen LM and Folsom AR and Siscovick DS and Mozaffarian D | Long-chain monounsaturated Fatty acids and incidence of congestive heart failure in 2 prospective cohorts. | Circulation | Not specifically n-3 intervention/exposure
23411152 | Kuhn T and Teucher B and Kaaks R and Boeing H and Weikert C and Buijsse B | Fish consumption and the risk of myocardial infarction and stroke in the German arm of the European Prospective Investigation into Cancer and Nutrition (EPIC-Germany). | The British Journal of Nutrition | Not specifically n-3 intervention/exposure
23134888 | Carvalho-Wells AL and Jackson KG and Lockyer S and Lovegrove JA and Minihane AM | APOE genotype influences triglyceride and C-reactive protein responses to altered dietary fat intake in UK adults. | The American Journal of Clinical Nutrition | Not specifically n-3 intervention/exposure
22917075 | Pintus S and Murru E and Carta G and Cordeddu L and Batetta B and Accossu S and Pistis D and Uda S and Elena Ghiani M and Mele M and Secchiari P and Almerighi G and Pintus P and Banni S | Sheep cheese naturally enriched in alpha-linolenic, conjugated linoleic and vaccenic acids improves the lipid profile and reduces anandamide in the plasma of hypercholesterolaemic subjects. | The British Journal of Nutrition | Not specifically n-3 intervention/exposure
22190026 | Horn LV and Tian L and Neuhouser ML and Howard BV and Eaton CB and Snetselaar L and Matthan NR and Lichtenstein AH | Dietary patterns are associated with disease risk among participants in the Women’s Health Initiative Observational Study. | The Journal of Nutrition | Not specifically n-3 intervention/exposure
21191140 | Larsson SC and Virtamo J and Wolk A | Fish consumption and risk of stroke in Swedish women. | The American Journal of Clinical Nutrition | Not specifically n-3 intervention/exposure
20713902 | A. M. S. Bernstein and Q. Hu and F. B. Stampfer and M. J. Manson and J. E. Willett and W. C. | Major dietary protein sources and risk of coronary heart disease in women | Circulation | Not specifically n-3 intervention/exposure
19893100 | Ristic-Medic D and Suzic S and Vucic V and Takic M and Tepsic J and Glibetic M | Serum and erythrocyte membrane phospholipids fatty acid composition in hyperlipidemia: effects of dietary intervention and combined diet and fibrate therapy. | General Physiology and Biophysics | Not specifically n-3 intervention/exposure
19755403 | Bjerregaard LJ and Joensen AM and Dethlefsen C and Jensen MK and Johnsen SP and Tjonneland A and Rasmussen LH and Overvad K and Schmidt EB | Fish intake and acute coronary syndrome. | European Heart Journal | Not specifically n-3 intervention/exposure
19713172 | Teas J and Baldeon ME and Chiriboga DE and Davis JR and Sarries AJ and Braverman LE | Could dietary seaweed reverse the metabolic syndrome? | Asia Pacific Journal of Clinical Nutrition | Not specifically n-3 intervention/exposure
19423109 | Vega-Lopez S and Matthan NR and Ausman LM and Ai M and Otokozawa S and Schaefer EJ and Lichtenstein AH | Substitution of vegetable oil for a partially-hydrogenated fat favorably alters cardiovascular disease risk factors in moderately hypercholesterolemic postmenopausal women. | Atherosclerosis | Not specifically n-3 intervention/exposure
19276620 | Garbagnati F and Cairella G and De Martino A and Multari M and Scognamiglio U and Venturiero V and Paolucci S | Is antioxidant and n-3 supplementation able to improve functional status in poststroke patients? Results from the Nutristroke Trial. | Cerebrovascular diseases (Basel, Switzerland) | Not specifically n-3 intervention/exposure
18678300 | Maki KC and McKenney JM and Reeves MS and Lubin BC and Dicklin MR | Effects of adding prescription omega-3 acid ethyl esters to simvastatin (20 mg/day) on lipids and lipoprotein particles in men and women with mixed dyslipidemia. | The American Journal of Cardiology | Not specifically n-3 intervention/exposure
17764599 | Messerer M and Hakansson N and Wolk A and Akesson A | Dietary supplement use and mortality in a cohort of Swedish men. | The British Journal of Nutrition | Not specifically n-3 intervention/exposure
17563030 | Fito M and Guxens M and Corella D and Saez G and Estruch R and de la Torre R and Frances F and Cabezas C and Lopez-Sabater Mdel C and Marrugat J and Garcia-Arellano A and Aros F and Ruiz-Gutierrez V and Ros E and Salas-Salvado J and Fiol M and Sola R and Covas MI | Effect of a traditional Mediterranean diet on lipoprotein oxidation: a randomized controlled trial. | Archives of Internal Medicine | Not specifically n-3 intervention/exposure
17381974 | Mukuddem-Petersen J and Stonehouse Oosthuizen W and Jerling JC and Hanekom SM and White Z | Effects of a high walnut and high cashew nut diet on selected markers of the metabolic syndrome: a controlled feeding trial. | The British Journal of Nutrition | Not specifically n-3 intervention/exposure
17237316 | Carrero JJ and Fonolla J and Marti JL and Jimenez J and Boza JJ and Lopez-Huertas E | Intake of fish oil, oleic acid, folic acid, and vitamins B-6 and E for 1 year decreases plasma C-reactive protein and reduces coronary heart disease risk factors in male patients in a cardiac rehabilitation program. | The Journal of Nutrition | Not specifically n-3 intervention/exposure
17010254 | Myint PK and Welch AA and Bingham SA and Luben RN and Wareham NJ and Day NE and Khaw KT | Habitual fish consumption and risk of incident stroke: the European Prospective Investigation into Cancer (EPIC)-Norfolk prospective population study. | Public Health Nutrition | Not specifically n-3 intervention/exposure
16054553 | Chisholm A and Mc Auley K and Mann J and Williams S and Skeaff M | Cholesterol lowering effects of nuts compared with a Canola oil enriched cereal of similar fat composition. | Nutrition, Metabolism, and Cardiovascular Diseases : NMCD | Not specifically n-3 intervention/exposure
15963403 | Mozaffarian D and Bryson CL and Lemaitre RN and Burke GL and Siscovick DS | Fish intake and risk of incident heart failure. | Journal of the American College of Cardiology | Not specifically n-3 intervention/exposure
15930443 | Carrero JJ and Lopez-Huertas E and Salmeron LM and Baro L and Ros E | Daily supplementation with (n-3) PUFAs, oleic acid, folic acid, and vitamins B-6 and E increases pain-free walking distance and improves risk factors in men with peripheral vascular disease. | The Journal of Nutrition | Not specifically n-3 intervention/exposure
15745721 | Nakamura Y and Ueshima H and Okamura T and Kadowaki T and Hayakawa T and Kita Y and Tamaki S and Okayama A | Association between fish consumption and all-cause and cause-specific mortality in Japan: NIPPON DATA80, 1980–99. | The American Journal of Medicine | Not specifically n-3 intervention/exposure
15668367 | Mozaffarian D and Longstreth WT Jr and Lemaitre RN and Manolio TA and Kuller LH and Burke GL and Siscovick DS | Fish consumption and stroke risk in elderly individuals: the cardiovascular health study. | Archives of Internal Medicine | Not specifically n-3 intervention/exposure
15668366 | Laaksonen DE1, Nyyssönen K, Niskanen L, Rissanen TH, Salonen JT. | Prediction of cardiovascular mortality in middle-aged men by dietary and serum linoleic and polyunsaturatedfatty acids. | Arch Intern Med. | Not specifically n-3 intervention/exposure
15514281 | Baylin A1, Campos H. | Arachidonic acid in adipose tissue is associated with nonfatal acute myocardial infarction in the central valley of Costa Rica. | J Nutr. | Not specifically n-3 intervention/exposure
15262826 | Mozaffarian D and Psaty BM and Rimm EB and Lemaitre RN and Burke GL and Lyles MF and Lefkowitz D and Siscovick DS | Fish intake and risk of incident atrial fibrillation. | Circulation | Not specifically n-3 intervention/exposure
15165614 | Carrero JJ and Baro L and Fonolla J and Gonzalez-Santiago M and Martinez-Ferez A and Castillo R and Jimenez J and Boza JJ and Lopez-Huertas E | Cardiovascular effects of milk enriched with omega-3 polyunsaturated fatty acids, oleic acid, folic acid, and vitamins E and B6 in volunteers with mild hyperlipidemia. | Nutrition (Burbank, Los Angeles County, Calif.) | Not specifically n-3 intervention/exposure
15159227 | Brady LM and Lovegrove SS and Lesauvage SV and Gower BA and Minihane AM and Williams CM and Lovegrove JA | Increased n-6 polyunsaturated fatty acids do not attenuate the effects of long-chain n-3 polyunsaturated fatty acids on insulin sensitivity or triacylglycerol reduction in Indian Asians. | The American Journal of Clinical Nutrition | Not specifically n-3 intervention/exposure
15087307 | Matthan NR and Welty FK and Barrett PH and Harausz C and Dolnikowski GG and Parks JS and Eckel RH and Schaefer EJ and Lichtenstein AH | Dietary hydrogenated fat increases high-density lipoprotein apoA-I catabolism and decreases low-density lipoprotein apoB-100 catabolism in hypercholesterolemic women. | Arteriosclerosis, Thrombosis, and Vascular Biology | Not specifically n-3 intervention/exposure
15051840 | Clifton PM1, Keogh JB, Noakes M. | Trans fatty acids in adipose tissue and the food supply are associated with myocardial infarction. | J Nutr. | Not specifically n-3 intervention/exposure
14717057 | Wang L1, Folsom AR, Eckfeldt JH. | Plasma fatty acid composition and incidence of coronary heart disease in middle aged adults: the Atherosclerosis Risk in Communities (ARIC) Study. | Nutr Metab Cardiovasc Dis. | Not specifically n-3 intervention/exposure
12663274 | Kark JD1, Kaufmann NA, Binka F, Goldberger N, Berry EM. | Adipose tissue n-6 fatty acids and acute myocardial infarction in a population consuming a diet high in polyunsaturated fatty acids. | Am J Clin Nutr. | Not specifically n-3 intervention/exposure
12653399 | R. F. M. Gillum and M. E. Madans and J. H. | Fish consumption and hypertension incidence in African Americans and whites: the NHANES I Epidemiologic Follow-up Study | Journal of the National Medical Association | Not specifically n-3 intervention/exposure
12642356 | Mozaffarian D and Lemaitre RN and Kuller LH and Burke GL and Tracy RP and Siscovick DS | Cardiac benefits of fish consumption may depend on the type of fish meal consumed: the Cardiovascular Health Study. | Circulation | Not specifically n-3 intervention/exposure
12433513 | Singh RB and Dubnov G and Niaz MA and Ghosh S and Singh R and Rastogi SS and Manor O and Pella D and Berry EM | Effect of an Indo-Mediterranean diet on progression of coronary artery disease in high risk patients (Indo-Mediterranean Diet Heart Study): a randomised single-blind trial. | Lancet | Not specifically n-3 intervention/exposure
11857049 | Tarpila S and Aro A and Salminen I and Tarpila A and Kleemola P and Akkila J and Adlercreutz H | The effect of flaxseed supplementation in processed foods on serum fatty acids and enterolactone. | European Journal of Clinical Nutrition | Not specifically n-3 intervention/exposure
11829698 | Jula A and Marniemi J and Huupponen R and Virtanen A and Rastas M and Ronnemaa T | Effects of diet and simvastatin on serum lipids, insulin, and antioxidants in hypercholesterolemic men: a randomized controlled trial. | JAMA | Not specifically n-3 intervention/exposure
11253967 | Oomen 2001 Holland | Association between trans fatty acid intake and 10-year risk of coronary heart disease in the Zutphen Elderly Study: a prospective population-based study. | Lancet. 2001 Mar10;357(9258):746–51. | Not specifically n-3 intervention/exposure
11226981 | Iso 2001 US (NHS) | Serum triglycerides and risk of coronary heart disease among Japanese men and women. | Am J Epidemiol. 2001 Mar 1;153(5):490–9. | Not specifically n-3 intervention/exposure
10760632 | Gillum RF1, Mussolino M, Madans JH. | The relation between fish consumption, death from all causes, and incidence of coronary heart disease. the NHANES I Epidemiologic Follow-up Study. | J Clin Epidemiol. 2000 Mar 1;53(3):237–44. | Not specifically n-3 intervention/exposure
10584044 | Hu 1999 US (NHS) | Dietary saturated fats and their food sources in relation to the risk of coronary heart disease in women. | Am J Clin Nutr. 1999 Dec;70(6):1001–8. | Not specifically n-3 intervention/exposure
10510585 | Kinjo Y, Beral V, Akiba S, Key T, Mizuno S, Appleby P, Yamaguchi N, Watanabe S, Doll R. | Possible protective effect of milk, meat and fish for cerebrovascular disease mortality in Japan. | J Epidemiol. 1999 Aug;9(4):268–74. | Not specifically n-3 intervention/exposure
10205349 | Leng GC, Lee AJ, Fowkes FG, Jepson RG, Lowe GD, Skinner ER, Mowat BF. | Randomized controlled trial of gamma-linolenic acid and eicosapentaenoic acid in peripheral arterial disease. | | Not specifically n-3 intervention/exposure
9989963 | DeLorgeril | Mediterranean diet, traditional risk factors, and the rate of cardiovascular complications after myocardial infarction: final report of the Lyon Diet Heart Study. | Circulation. 1999 Feb 16;99(6):779–85. | Not specifically n-3 intervention/exposure
9415002 | Mann JI, Appleby PN, Key TJ, Thorogood M. | Dietary determinants of ischaemic heart disease in health conscious individuals. | Heart. 1997 Nov;78(5):450–5. | Not specifically n-3 intervention/exposure
9343002 | Fraser 1997 | Risk factors for all-cause and coronary heart disease mortality in the oldest-old. The Adventist Health Study. | Arch Intern Med. 1997 Oct 27;157(19):2249–58. | Not specifically n-3 intervention/exposure
8610699 | Gillum RF, Mussolino ME, Ingram DD. | Physical activity and stroke incidence in women and men. The NHANES I Epidemiologic Follow-up Study. | Am J Epidemiol. 1996 May 1;143(9):860–9. | Not specifically n-3 intervention/exposure
8604960 | Gillum RF1, Mussolino ME, Madans JH. | The relationship between fish consumption and stroke incidence. The NHANES I Epidemiologic Follow-up Study (National Health and Nutrition Examination Survey). | Arch Intern Med. | Not specifically n-3 intervention/exposure
8280516 | Roberts TL1, Wood DA, Riemersma RA, Gallagher PJ, Lampe FC. | Linoleic acid and risk of sudden cardiac death. | Br Heart J. | Not specifically n-3 intervention/exposure
7911176 | de Lorgeril M., Renaud S., Mamelle N., Salen P., Martin JL., Monjaud I., Guidollet J., Touboul P., Delaye J. | Mediterranean alpha-linolenic acid-rich diet in secondary prevention of coronary heart disease. | Lancet; 1994, 343–8911 | Not specifically n-3 intervention/exposure
5228820 | Leren P | The effect of plasma cholesterol lowering diet in male survivors of myocardial infarction. A controlled clinical trial. | Acta Med Scand Suppl. 1966;466:1–92. | Not specifically n-3 intervention/exposure
1638709 | Fraser 1992a US (adventist) | Effects of traditional coronary risk factors on rates of incident coronary events in a low-risk population. The Adventist Health Study. | Circulation. 1992 Aug;86(2):406–13. | Not specifically n-3 intervention/exposure
1617510 | Bairati I., Roy L., Meyer F. | Effects of a fish oil supplement on blood pressure and serum lipids in patients treated for coronary artery disease. | The Canadian Journal of Cardiology, 8-1 | Not specifically n-3 intervention/exposure
24638908 | Bonds DE and Harrington M and Worrall BB and Bertoni AG and Eaton CB and Hsia J and Robinson J and Clemons TE and Fine LJ and Chew EY | Effect of long-chain omega-3 fatty acids and lutein + zeaxanthin supplements on cardiovascular outcomes: results of the Age-Related Eye Disease Study 2 (AREDS2) randomized clinical trial. | JAMA Internal Medicine | P: Not general population (macular degeneration)
none | A. R. N. Rahbar and I. Amiri and Z. | Effects of omega-3 fatty acids on serum lipids and high sensitivity C reactive protein in cigarette smokers | Journal of Biological Sciences | Parallel RCT N<30/arm
none | A. S. B. J. G. M. Venkata Krishnan P | Effects of low dose omega-3 fatty acids on platelet functions and coagulation profile in Indian patients with type 2 diabetes mellitus with vascular complications: A prospective, preliminary study | Journal, Indian Academy of Clinical Medicine | Parallel RCT N<30/arm
none | A. Yates and Norwig and J. and Maroon and J. C. and Bost and J. and Bradley and J. P. and Duca and M. and Wecht and D. A. and Grove and R. and Iso and A. and Cobb and I. and Ross and N. and Borden and M. | Evaluation of lipid profiles and the use of omega-3 essential fatty acid in professional football players | | Parallel RCT N<30/arm
none | F. P. Garmendia and R. Ronceros and G. | Effect of sacha inchi oil (Plukenetia volubilis L) on the lipid profile of patients with Hyperlipoproteinemia | Revista Peruana de Medicina de Experimental y Salud Publica | Parallel RCT N<30/arm
none | F. Shidfar and Keshavarz and A. and Jalali and M. and Miri and R. and Amri and A. and Shidfar and S. H. | Effects of purified omega-3 fatty acids on serum lipoproteins and malondialdehyde in postmenopausal fat women receiving hormone replacement therapy | | Parallel RCT N<30/arm
none | H. Rus and Radoi and M. and Ciurea and C. and Nan and M. and Suta and C. and Boda and D. | Effect of treatment with omega-3 fattyacids and atorvastatin in patients with combined dyslipidemia | | Parallel RCT N<30/arm
none | J. Coad and Morel and P. C. H. and Booth and C. | Effect of consuming pork meat enriched with long chain omega 3 fatty acids and selenium on markers of cardiovascular disease | Proceedings of the Massey University Advancing Pork Production Seminar, Palmerston North, New Zealand, 7th June | Parallel RCT N<30/arm
none | J. D. B. Buckley and S. Murphy and K. J. Howe and P. R. C. | DHA-rich fish oil lowers heart rate during submaximal exercise in elite Australian Rules footballers | Journal of Science and Medicine in Sport | Parallel RCT N<30/arm
none | K. P. V. A. R. G. M. B. J. Bhise A | Effect of low-dose omega-3 fatty acids substitution on blood pressure, hyperinsulinemia and dyslipidemia in Indians with essential hypertension: A pilot study | Indian Journal of Clinical Biochemistry | Parallel RCT N<30/arm
none | M. J. M. H. W. S. Isley WI | Pilot study of combined therapy with -3 fatty acids and niacin in atherogenic dyslipidemia | Journal of Clinical Lipidology | Parallel RCT N<30/arm
none | S. U. S. L. S. D. M. V. D. K. A. J. S. P. A.- K. M. U. M. I. J. Erkkila At | Effect of fatty and lean fish intake on lipoprotein subclasses in subjects with coronary heart disease: A controlled trial | Journal of Clinical Lipidology | Parallel RCT N<30/arm
none | W. R. S. T. Liu M | Effect of bread containing stable fish oil on plasma phospholipid fatty acids, triglycerides, HDL-cholesterol, and malondialdehyde in subjects with hyperlipidemia | Nutrition Research (New York, N.Y.) | Parallel RCT N<30/arm
8908382eag | Rossing P., Hansen BV., Nielsen FS., Myrup B., Hølmer G., Parving HH. | Fish oil in diabetic nephropathy. | Diabetes Care; 1996, 19–11 | Parallel RCT N<30/arm
24290606 | Simao AN and Lozovoy MA and Dichi I | Effect of soy product kinako and fish oil on serum lipids and glucose metabolism in women with metabolic syndrome. | Nutrition (Burbank, Los Angeles County, Calif.) | Parallel RCT N<30/arm
23888318 | Hlais S and El-Bistami D and El Rahi B and Mattar MA and Obeid OA | Combined fish oil and high oleic sunflower oil supplements neutralize their individual effects on the lipid profile of healthy men. | Lipids | Parallel RCT N<30/arm
23375525 | Guebre-Egziabher F and Debard C and Drai J and Denis L and Pesenti S and Bienvenu J and Vidal H and Laville M and Fouque D | Differential dose effect of fish oil on inflammation and adipose tissue gene expression in chronic kidney disease patients. | Nutrition (Burbank, Los Angeles County, Calif.) | Parallel RCT N<30/arm
23332800 | Dawczynski C and Massey KA and Ness C and Kiehntopf M and Stepanow S and Platzer M and Grun M and Nicolaou A and Jahreis G | Randomized placebo-controlled intervention with n-3 LC-PUFA- supplemented yoghurt: effects on circulating eicosanoids and cardiovascular risk factors. | Clinical Nutrition (Edinburgh, Scotland) | Parallel RCT N<30/arm
22952598 | Ottestad I and Hassani S and Borge GI and Kohler A and Vogt G and Hyotylainen T and Oresic M and Bronner KW and Holven KB and Ulven SM and Myhrstad MC | Fish oil supplementation alters the plasma lipidomic profile and increases long-chain PUFAs of phospholipids and triglycerides in healthy subjects. | PloS one | Parallel RCT N<30/arm
22773687 | Ooi EM and Lichtenstein AH and Millar JS and Diffenderfer MR and Lamon-Fava S and Rasmussen H and Welty FK and Barrett PH and Schaefer EJ | Effects of Therapeutic Lifestyle Change diets high and low in dietary fish-derived FAs on lipoprotein metabolism in middle-aged and elderly subjects. | Journal of Lipid Research | Parallel RCT N<30/arm
22293584 | Sasaki J and Miwa T and Odawara M | Administration of highly purified eicosapentaenoic acid to statin-treated diabetic patients further improves vascular function. | Endocrine Journal | Parallel RCT N<30/arm
21701083 | Takaki A and Umemoto S and Ono K and Seki K and Ryoke T and Fujii A and Itagaki T and Harada M and Tanaka M and Yonezawa T and Ogawa H and Matsuzaki M | Add-on therapy of EPA reduces oxidative stress and inhibits the progression of aortic stiffness in patients with coronary artery disease and statin therapy: a randomized controlled study. | Journal of Atherosclerosis and Thrombosis | Parallel RCT N<30/arm
21543294 | Ozaydin M and Erdogan D and Tayyar S and Uysal BA and Dogan A and Icli A and Ozkan E and Varol E and Turker Y and Arslan A | N-3 polyunsaturated fatty acids administration does not reduce the recurrence rates of atrial fibrillation and inflammation after electrical cardioversion: a prospective randomized study. | Anadolu Kardiyoloji Dergisi : AKD = The Anatolian Journal of Cardiology | Parallel RCT N<30/arm
21232631 | Kumar S and Sutherland F and Wheeler M and Heck PM and Lee G and Teh AW and Garg ML and Morgan JG and Sparks PB | Effects of chronic omega-3 polyunsaturated fatty acid supplementation on human atrial mechanical function after reversion of atrial arrhythmias to sinus rhythm: reversal of tachycardia-mediated atrial cardiomyopathy with fish oils. | Heart Rhythm : the Official Journal of the Heart Rhythm Society | Parallel RCT N<30/arm
20303788 | Bouzidi N and Mekki K and Boukaddoum A and Dida N and Kaddous A and Bouchenak M | Effects of omega-3 polyunsaturated fatty-acid supplementation on redox status in chronic renal failure patients with dyslipidemia. | Journal of Renal Nutrition : The Official Journal of the Council on Renal Nutrition of the National Kidney Foundation | Parallel RCT N<30/arm
20125104 | van Hees AM and Saris WH and Hul GB and Schaper NC and Timmerman BE and Lovegrove JA and Roche HM and Blaak EE | Effects of dietary fat modification on skeletal muscle fatty acid handling in the metabolic syndrome. | International Journal of Obesity (2005) | Parallel RCT N<30/arm
19854375 | Maki KC and Reeves MS and Farmer M and Griinari M and Berge K and Vik H and Hubacher R and Rains TM | Krill oil supplementation increases plasma concentrations of eicosapentaenoic and docosahexaenoic acids in overweight and obese men and women. | Nutrition Research (New York, N.Y.) | Parallel RCT N<30/arm
19390588 | Lankinen M and Schwab U and Erkkila A and Seppanen-Laakso T and Hannila ML and Mussalo H and Lehto S and Uusitupa M and Gylling H and Oresic M | Fatty fish intake decreases lipids related to inflammation and insulin signaling--a lipidomics approach. | PloS one | Parallel RCT N<30/arm
19261730 | Egert S and Kannenberg F and Somoza V and Erbersdobler HF and Wahrburg U | Dietary alpha-linolenic acid, EPA, and DHA have differential effects on LDL fatty acid composition but similar effects on serum lipid profiles in normolipidemic humans. | The Journal of Nutrition | Parallel RCT N<30/arm
18665413 | Erkkila AT and Schwab US and de Mello VD and Lappalainen T and Mussalo H and Lehto S and Kemi V and Lamberg-Allardt C and Uusitupa MI | Effects of fatty and lean fish intake on blood pressure in subjects with coronary heart disease using multiple medications. | European Journal of Nutrition | Parallel RCT N<30/arm
18460481 | Kaul N and Kreml R and Austria JA and Richard MN and Edel AL and Dibrov E and Hirono S and Zettler ME and Pierce GN | A comparison of fish oil, flaxseed oil and hempseed oil supplementation on selected parameters of cardiovascular health in healthy volunteers. | Journal of the American College of Nutrition | Parallel RCT N<30/arm
17805229 | Wang S and Ma AQ and Song SW and Quan QH and Zhao XF and Zheng XH | Fish oil supplementation improves large arterial elasticity in overweight hypertensive patients. | European Journal of Clinical Nutrition | Parallel RCT N<30/arm
17510682 | Thomas TR and Liu Y and Linden MA and Rector RS | Interaction of exercise training and n-3 fatty acid supplementation on postprandial lipemia. | Applied Physiology, Nutrition, and Metabolism = Physiologie Appliquee, Nutrition et Metabolisme | Parallel RCT N<30/arm
17327864 | Mostad IL and Bjerve KS and Lydersen S and Grill V | Effects of marine n-3 fatty acid supplementation on lipoprotein subclasses measured by nuclear magnetic resonance in subjects with type II diabetes. | European Journal of Clinical Nutrition | Parallel RCT N<30/arm
16781788 | Patel JV and Lee KW and Tomson J and Dubb K and Hughes EA and Lip GY | Effects of omega-3 polyunsaturated fatty acids on metabolically active hormones in patients post-myocardial infarction. | International Journal of cCardiology | Parallel RCT N<30/arm
16482073 | Goyens PL and Mensink RP | Effects of alpha-linolenic acid versus those of EPA/DHA on cardiovascular risk markers in healthy elderly subjects. | European Journal of Clinical Nutrition | Parallel RCT N<30/arm
16317123 | Goyens PL and Mensink RP | The dietary alpha-linolenic acid to linoleic acid ratio does not affect the serum lipoprotein profile in humans. | The Journal of Nutrition | Parallel RCT N<30/arm
16278686 | Wu WH and Lu SC and Wang TF and Jou HJ and Wang TA | Effects of docosahexaenoic acid supplementation on blood lipids, estrogen metabolism, and in vivo oxidative stress in postmenopausal vegetarian women. | European Journal of Clinical Nutrition | Parallel RCT N<30/arm
15250255 | Hong H and Xu ZM and Pang BS and Cui L and Wei Y and Guo WJ and Mao YL and Yang XC | Effects of simvastain combined with omega-3 fatty acids on high sensitive C-reactive protein, lipidemia, and fibrinolysis in patients with mixed dyslipidemia. | Chinese Medical Sciences Journal = Chung-kuo i hsueh k’o hsueh tsa chih / Chinese Academy of Medical Sciences | Parallel RCT N<30/arm
15226460 | Li Z and Lamon-Fava S and Otvos J and Lichtenstein AH and Velez-Carrasco W and McNamara JR and Ordovas JM and Schaefer EJ | Fish consumption shifts lipoprotein subfractions to a less atherogenic pattern in humans. | The Journal of Nutrition | Parallel RCT N<30/arm
12871402 | Nordoy A and Svensson B and Hansen JB | Atorvastatin and omega-3 fatty acids protect against activation of the coagulation system in patients with combined hyperlipemia. | Journal of Thrombosis and Haemostasis : JTH | Parallel RCT N<30/arm
12540386 | Chan DC and Watts GF and Mori TA and Barrett PH and Redgrave TG and Beilin LJ | Randomized controlled trial of the effect of n-3 fatty acid supplementation on the metabolism of apolipoprotein B-100 and chylomicron remnants in men with visceral obesity. | The American Journal of Clinical Nutrition | Parallel RCT N<30/arm
12421024 | Jain S and Gaiha M and Bhattacharjee J and Anuradha S | Effects of low-dose omega-3 fatty acid substitution in type-2 diabetes mellitus with special reference to oxidative stress--a prospective preliminary study. | The Journal of the Association of Physicians of India | Parallel RCT N<30/arm
12399272 | Woodman RJ and Mori TA and Burke V and Puddey IB and Watts GF and Beilin LJ | Effects of purified eicosapentaenoic and docosahexaenoic acids on glycemic control, blood pressure, and serum lipids in type 2 diabetic patients with treated hypertension. | The American Journal of Clinical Nutrition | Parallel RCT N<30/arm
12370843 | Karvonen HM and Aro A and Tapola NS and Salminen I and Uusitupa MI and Sarkkinen ES | Effect of alpha-linolenic acid-rich Camelina sativa oil on serum fatty acid composition and serum lipids in hypercholesterolemic subjects. | Metabolism: Clinical and Experimental | Parallel RCT N<30/arm
12351465 | Petersen M and Pedersen H and Major-Pedersen A and Jensen T and Marckmann P | Effect of fish oil versus corn oil supplementation on LDL and HDL subclasses in type 2 diabetic patients. | Diabetes Care | Parallel RCT N<30/arm
12145002 | Nestel P and Shige H and Pomeroy S and Cehun M and Abbey M and Raederstorff D | The n-3 fatty acids eicosapentaenoic acid and docosahexaenoic acid increase systemic arterial compliance in humans. | The American Journal of Clinical Nutrition | Parallel RCT N<30/arm
11925466 | Kratz M and Gulbahce E and von Eckardstein A and Cullen P and Cignarella A and Assmann G and Wahrburg U | Dietary mono- and polyunsaturated fatty acids similarly affect LDL size in healthy men and women. | The Journal of Nutrition | Parallel RCT N<30/arm
10919932 | Stark KD and Park EJ and Maines VA and Holub BJ | Effect of a fish-oil concentrate on serum lipids in postmenopausal women receiving and not receiving hormone replacement therapy in a placebo-controlled, double-blind trial. | The American Journal of Clinical Nutrition | Parallel RCT N<30/arm
8112187 | Axelrod L., Camuso J., Williams E., Kleinman K., Briones E., Schoenfeld D. | Effects of a small quantity of omega-3 fatty acids on cardiovascular risk factors in NIDDM. A randomized, prospective, double-blind, controlled study. | Diabetes Care. 1994 Jan;17(1):37–44. | Parallel RCT N<30/arm
3020732 | Haines AP., Sanders TA., Imeson JD., Mahler RF., Martin J., Mistry M., Vickers M., Wallace PG. | Effects of a fish oil supplement on platelet function, haemostatic variables and albuminuria in insulin-dependent diabetics. | Thrombosis Research; 1986, 43–6 | Parallel RCT N<30/arm
19487105 | Ramel A and Martinez JA and Kiely M and Bandarra NM and Thorsdottir I | Moderate consumption of fatty fish reduces diastolic blood pressure in overweight and obese European young adults during energy restriction. | Nutrition (Burbank, Los Angeles County, Calif.) | Weight loss intervention
18029476 | Plat J and Jellema A and Ramakers J and Mensink RP | Weight loss, but not fish oil consumption, improves fasting and postprandial serum lipids, markers of endothelial function, and inflammatory signatures in moderately obese men. | The Journal of Nutrition | Weight loss intervention
15361771 | Mori TA and Burke V and Puddey IB and Shaw JE and Beilin LJ | Effect of fish diets and weight loss on serum leptin concentration in overweight, treated-hypertensive subjects. | Journal of Hypertension | Weight loss intervention
8918511 | Anderssen SA., Hjermann I., Urdal P., Torjesen PA., Holme I. | Improved carbohydrate metabolism after physical training and dietary intervention in individuals with the “atherothrombogenic syndrome’. Oslo Diet and Exercise Study (ODES). A randomized trial. | Journal of Internal Medicine. 1996 Oct; 240(4): 203–9 | Weight loss intervention
1586398 | | The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. | JAMA. | Weight loss intervention
none | S. S. B. P. S. L. E. K. M. W. R. C. L. N. M. Sindelar Ca | Serum lipids of physically active adults consuming omega-3 fatty acid-enriched eggs or conventional eggs | Nutrition Research (New York, N.Y.) | XO N<20
none | K. C. L. Maki and B. C. Reeves and M. S. Dicklin and M. R. Harris and W. S. | Prescription omega-3 acid ethyl esters plus simvastatin 20 and 80 mg: effects in mixed dyslipidemia | Journal of Clinical Lipidology | XO N<20
none | L. N. M. S. S. E. C. T. P. Lee J-Y | Consumption of omega-3 fatty acid-enriched eggs and serum lipids in humans | Journal of Nutraceuticals, Functional and Medical Foods | XO N<20
none | R. L. Purcell and S. H. Botham and K. H. Hall and W. L. Wheeler-Jones and C. P. D. | High-fat meals rich in EPA plus DHA compared with DHA only have differential effects on postprandial lipemia and plasma 8-isoprostane F2(alpha)concentrations relative to a control high-oleic acid meal: A randomized controlled trial | American Journal of Clinical Nutrition | XO N<20
22182482 | Lee SP and Dart AM and Walker KZ and O’Dea K and Chin-Dusting JP and Skilton MR | Effect of altering dietary n-6:n-3 PUFA ratio on cardiovascular risk measures in patients treated with statins: a pilot study. | The British Journal of Nutrition | XO N<20
21775113 | Maki KC and Lawless AL and Kelley KM and Dicklin MR and Schild AL and Rains TM | Prescription omega-3-acid ethyl esters reduce fasting and postprandial triglycerides and modestly reduce pancreatic beta-cell response in subjects with primary hypertriglyceridemia. | Prostaglandins, Leukotrienes, and Essential Fatty Acids | XO N<20
19824016 | Coulman KD and Liu Z and Michaelides J and Quan Hum W and Thompson LU | Fatty acids and lignans in unground whole flaxseed and sesame seed are bioavailable but have minimal antioxidant and lipid-lowering effects in postmenopausal women. | Molecular Nutrition & Food Research | XO N<20
19215678 | Utarwuthipong T and Komindr S and Pakpeankitvatana V and Songchitsomboon S and Thongmuang N | Small dense low-density lipoprotein concentration and oxidative susceptibility changes after consumption of soybean oil, rice bran oil, palm oil and mixed rice bran/palm oil in hypercholesterolaemic women. | The Journal of International Medical Research | XO N<20
18991244 | Ohman M and Akerfeldt T and Nilsson I and Rosen C and Hansson LO and Carlsson M and Larsson A | Biochemical effects of consumption of eggs containing omega-3 polyunsaturated fatty acids. | Upsala Journal of Medical Sciences | XO N<20
17268414 | Lindqvist H and Langkilde AM and Undeland I and Radendal T and Sandberg AS | Herring (Clupea harengus) supplemented diet influences risk factors for CVD in overweight subjects. | European Journal of Clinical Nutrition | XO N<20
17103080 | Schwab US and Callaway JC and Erkkila AT and Gynther J and Uusitupa MI and Jarvinen T | Effects of hempseed and flaxseed oils on the profile of serum lipids, serum total and lipoprotein lipid concentrations and haemostatic factors. | European Journal of Nutrition | XO N<20
16825681 | Vega-Lopez S and Ausman LM and Jalbert SM and Erkkila AT and Lichtenstein AH | Palm and partially hydrogenated soybean oils adversely alter lipoprotein profiles compared with soybean and canola oils in moderately hyperlipidemic subjects. | The American Journal of Clinical Nutrition | XO N<20
16616012 | O’Keefe JH Jr and Abuissa H and Sastre A and Steinhaus DM and Harris WS | Effects of omega-3 fatty acids on resting heart rate, heart rate recovery after exercise, and heart rate variability in men with healed myocardial infarctions and depressed ejection fractions. | The American Journal of Cardiology | XO N<20
15936647 | Tahvonen RL and Schwab US and Linderborg KM and Mykkanen HM and Kallio HP | Black currant seed oil and fish oil supplements differ in their effects on fatty acid profiles of plasma lipids, and concentrations of serum total and lipoprotein lipids, plasma glucose and insulin. | The Journal of Nutritional Biochemistry | XO N<20
14767865 | Calabresi L and Villa B and Canavesi M and Sirtori CR and James RW and Bernini F and Franceschini G | An omega-3 polyunsaturated fatty acid concentrate increases plasma high-density lipoprotein 2 cholesterol and paraoxonase levels in patients with familial combined hyperlipidemia. | Metabolism: Clinical and Experimental | XO N<20
12162948 | Villa B and Calabresi L and Chiesa G and Rise P and Galli C and Sirtori CR | Omega-3 fatty acid ethyl esters increase heart rate variability in patients with coronary disease. | Pharmacological Research : The Official Journal of the Italian Pharmacological Society | XO N<20
11675948 | Miyajima T and Tsujino T and Saito K and Yokoyama M | Effects of eicosapentaenoic acid on blood pressure, cell membrane fatty acids, and intracellular sodium concentration in essential hypertension. | Hypertension Research : Official Journal of the Japanese Society of Hypertension | XO N<20
10657575 | Calabresi L and Donati D and Pazzucconi F and Sirtori CR and Franceschini G | Omacor in familial combined hyperlipidemia: effects on lipids and low density lipoprotein subclasses. | Atherosclerosis | XO N<20