# Appendix A Search Strategy

Table A-1 Primary update of omega-3 fatty acid and CVD search in Ovid

For outcomes included in original omega-3 fatty acid and CVD report

Limited to 2002–2015. Search run on June 8, 2015.

Databases: MEDLINE®, Cochrane Central Trials Registry® and Cochrane Database of Systematic Reviews®, CAB Abstracts®. All in Ovid.

# | Search
1. | exp fatty acids, omega-3/ | Omega 3 terms
2. | ((omega-3 or omega 3 or omega3) and fatty acid$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
3. | fatty acids, essential/ | Omega 3 terms
4. | linolenic acids/ | Omega 3 terms
5. | exp fish oils/ | Omega 3 terms
6. | ((n 3 or n3 or n-3) and (oil$ or pufa or fatty acid$ or omega 3)).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
7. | Docosahexaenoic Acids/ | Omega 3 terms
8. | docosahexa?noic.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] or docosapenta?noic.mp. | Omega 3 terms
9. | Eicosapentaenoic Acid/ | Omega 3 terms
10. | eicosapenta?noic.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
11. | icosapent?enoic.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
12. | (alpha linolenic or alphalinolenic or alpha-linolenic).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
13. | (linolenate or cervonic or timnodonic or stearidonic).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
14. | menhaden oil$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
15. | ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or perilla or shiso) adj2 oil$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
16. | (walnut$ or butternut$ or soybean$ or pumpkin seed$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
17. | (fish adj2 oil$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
18. | (cod liver oil$ or codliver oil$ or marine oil$ or marine fat$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
19. | (salmon or mackerel or herring or tuna or halibut or seaweed or anchov$ or sardine$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
20. | (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega or Lovaza or Vascepa or icosapent ethyl).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
21. | (fish consumption or fish intake or (fish adj2 diet$)).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
22. | (mediterranean adj diet$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Omega 3 terms
23. | ((red blood cell or phospholipid or plasma fatty acid or plasma or phospholipid or triacylglycerol or cholesteryl or ester or adipos$ or fatty acid or erythrocyte or ghost or platelet or granulocyte or neutrophil or mononuclear or LDL or HDL) and (DHA or docosahexa?noic or docosapenta?noic or EPA or eicosapenta?noic or SDA or linolenic or stearidonic or omega)).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | n-3 Biomarkers
24. | or/1–23 | n-3
25. | exp cardiovascular diseases/ | Cardiovascular diseases, risk factors, adverse events
26. | atherosclero$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
27. | Arteriosclero$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
28. | cardioprotect$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
29. | Coronary.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
30. | heart disease$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
31. | Myocardial infarct$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
32. | exp Cerebrovascular Accident/ | Cardiovascular diseases, risk factors, adverse events
33. | stroke.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
34. | (Transient Ischemic Attack or TIA).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
35. | exp lipids/ | Cardiovascular diseases, risk factors, adverse events
36. | lipid$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
37. | exp cholesterol/ | Cardiovascular diseases, risk factors, adverse events
38. | cholesterol.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
39. | exp Lipoproteins, LDL/ | Cardiovascular diseases, risk factors, adverse events
40. | exp Lipoproteins, HDL/ | Cardiovascular diseases, risk factors, adverse events
41. | exp triglycerides/ | Cardiovascular diseases, risk factors, adverse events
42. | triglycerides.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
43. | exp Hyperlipidemias/ | Cardiovascular diseases, risk factors, adverse events
44. | hypertriglyceridem$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
45. | hyperlipidemia$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
46. | exp dyslipidemias/ | Cardiovascular diseases, risk factors, adverse events
47. | dyslipidemia$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
48. | exp blood pressure/ | Cardiovascular diseases, risk factors, adverse events
49. | blood pressure.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
50. | (diastol$ or systol$ or mean arterial).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
51. | exp hypertension/ | Cardiovascular diseases, risk factors, adverse events
52. | hypertension.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
53. | exp Hemorrhage/ | Cardiovascular diseases, risk factors, adverse events
54. | hemorrhag$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
55. | bleeding.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Cardiovascular diseases, risk factors, adverse events
56. | or/25–55 | Cardiovascular diseases, risk factors, adverse events
57. | 24 and 56 | n-3 & CVD
58. | (random$ or rct$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
59. | exp randomized controlled trials/ | Study designs
60. | exp Randomized Controlled Trials as Topic/ | Study designs
61. | exp random allocation/ | Study designs
62. | exp double-blind method/ | Study designs
63. | exp single-blind method/ | Study designs
64. | randomized controlled trial.pt. | Study designs
65. | clinical trial.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
66. | (clin$ adj trial$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
67. | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
68. | exp placebos/ | Study designs
69. | placebo$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
70. | randomly allocated.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
71. | (allocated adj2 random$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
72. | comparative study.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
73. | follow-up studies/ | Study designs
74. | (follow up or followup).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
75. | exp case-control studies/ | Study designs
76. | (case adj20 control).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
77. | exp longitudinal studies/ | Study designs
78. | longitudinal.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
79. | exp cohort studies/ | Study designs
80. | cohort.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
81. | exp prospective studies/ | Study designs
82. | exp evaluation studies/ | Study designs
83. | (observational adj (study or studies)).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
84. | Cross-Sectional Studies/ | Study designs
85. | (cross section$ or cross-section$).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
86. | food frequency questionnaire$.mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc] | Study designs
87. | or/58–86 | Study designs
88. | 57 and 87 | n-3, CVD, Designs
89. | limit 88 to (addresses or autobiography or bibliography or biography or case reports or comment or congresses or dictionary or directory or editorial or festschrift or government publications or historical article or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index) | Not non-studies
90. | 88 not 89 | Not non-studies
91. | limit 90 to english language | Limits
92. | limit 91 to humans | Limits
93. | (guidelines or practice guideline or meta analysis or systematic review).pt. | SRs, GLs
94. | (systematic$ adj3 review$).tw. | SRs, GLs
95. | 93 or 94 | SRs, GLs
96. | 57 and 95 | SRs, GLs
97. | limit 96 to yr=“2002 – 2015” | Non-SRs
98. | 92 not 96 | SRs
99. | limit 98 to yr=“2002 – 2015” | SRs

Table A-2 New search of omega-3 fatty acid and CVD for new outcomes in Ovid

For outcomes included in original omega-3 fatty acid and CVD report

Dates: 2000 to June 8, 2015.

Databases: MEDLINE®, Cochrane Central Trials Registry® and Cochrane Database of Systematic Reviews®, CAB Abstracts®. All in Ovid.

# | Search
1. | exp fatty acids, omega-3/
2. | ((omega-3 or omega 3 or omega3) and fatty acid$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
3. | fatty acids, essential/
4. | linolenic acids/
5. | exp fish oils/
6. | ((n 3 or n3 or n-3) and (oil$ or pufa or fatty acid$ or omega 3)).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
7. | Docosahexaenoic Acids/
8. | docosahexa?noic.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc] or docosapenta?noic.mp.
9. | Eicosapentaenoic Acid/
10. | eicosapenta?noic.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
11. | icosapent?enoic.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
12. | (alpha linolenic or alphalinolenic or alpha-linolenic).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
13. | (linolenate or cervonic or timnodonic or stearidonic).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
14. | menhaden oil$.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
15. | ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or perilla or shiso) adj2 oil$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
16. | (walnut$ or butternut$ or soybean$ or pumpkin seed$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
17. | (fish adj2 oil$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
18. | (cod liver oil$ or codliver oil$ or marine oil$ or marine fat$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
19. | (salmon or mackerel or herring or tuna or halibut or seaweed or anchov$ or sardine$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
20. | (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega or Lovaza or Vascepa or icosapent ethyl).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
21. | (fish consumption or fish intake or (fish adj2 diet$)).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
22. | (mediterranean adj diet$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
23. | ((red blood cell or phospholipid or plasma fatty acid or plasma or phospholipid or triacylglycerol or cholesteryl or ester or adipos$ or fatty acid or erythrocyte or ghost or platelet or granulocyte or neutrophil or mononuclear or LDL or HDL) and (DHA or docosahexa?noic or Docosapenta?noic or EPA or eicosapenta?noic or SDA or linolenic or stearidonic or omega)).mp. [mp=ti, ab, ot, nm, hw, kf, px, rx, ui, tx, kw, ct, sh, bt, id, cc]
24. | or/1–23
25. | (random$ or rct$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
26. | exp randomized controlled trials/
27. | exp Randomized Controlled Trials as Topic/
28. | exp random allocation/
29. | exp double-blind method/
30. | exp single-blind method/
31. | randomized controlled trial.pt.
32. | clinical trial.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
33. | (clin$ adj trial$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
34. | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
35. | exp placebos/
36. | placebo$.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
37. | randomly allocated.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
38. | (allocated adj2 random$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
39. | comparative study.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
40. | follow-up studies/
41. | (follow up or followup).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
42. | exp case-control studies/
43. | (case adj20 control).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
44. | exp longitudinal studies/
45. | longitudinal.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
46. | exp cohort studies/
47. | cohort.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
48. | exp prospective studies/
49. | exp evaluation studies/
50. | (observational adj (study or studies)).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
51. | Cross-Sectional Studies/
52. | (cross section$ or cross-section$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
53. | food frequency questionnaire$.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
54. | or/25–53
55. | 24 and 54
56. | exp heart failure/
57. | Heart failure$.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
58. | exp pulmonary edema/
59. | pulmonary edema.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
60. | pulmonary oedema.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
61. | (ejection adj2 fraction).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
62. | exp peripheral vascular diseases/
63. | (peripheral and vascular and disease$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
64. | claudication.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
65. | exp arrhythmias, cardiac/
66. | (arrhythmi$ or Antiarrhythmi$).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
67. | Fibrillation.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
68. | Flutter.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
69. | exp tachycardia/
70. | tachycardia.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
71. | tachyarrhythmia.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
72. | exp bradycardia/
73. | bradycardia.mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
74. | exp death, sudden/
75. | (sudden adj death).mp. [mp=ti, ot, ab, nm, hw, kw, kf, px, rx, ui, an, tx, sh, ct, bt, id, cc]
76. | or/56–75
77. | 24 and 54 and 76
78. | limit 77 to (addresses or autobiography or bibliography or biography or case reports or comment or congresses or dictionary or directory or editorial or festschrift or government publications or historical article or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index)
79. | 77 not 78
80. | limit 79 to english language
81. | limit 80 to humans
82. | (guidelines or practice guideline or meta analysis or systematic review).pt.
83. | (systematic$ adj3 review$).tw.
84. | 82 or 83
85. | 24 and 76 and 84
86. | 81 not 85

Table A-3 Searches run in EMBASE®

All outcomes

Dates: 2000 to June 8, 2015.

EMBASE®

Search 1 fatty AND acids, AND essential OR essential AND fatty AND ('acids'/exp OR acids) OR (n AND 3 OR n3 OR 'n 3' AND (oil* OR pufa OR fatty AND acid* OR omega AND 3 OR omega3 OR 'omega 3')) OR docosahexa*noic OR docosapenta*noic OR eicosapenta*noic OR icosapent*enoic OR (alpha AND linolenic OR alphalinolenic OR 'alpha linolenic' OR linolenic AND acids) OR (linoleic AND acid) OR cervonic OR timnodonic OR stearidonic OR (flaxseed OR flax AND seed OR linseed OR rape AND seed OR rapeseed OR canola OR soy OR soybean OR walnut OR mustard AND seed OR perilla OR shiso OR menhaden OR fish AND oil*) OR (walnut* OR butternut* OR soybean* OR pumpkin AND seed*) OR (cod AND liver AND oil* OR codliver AND oil* OR marine AND oil* OR marine AND fat*) OR salmon OR mackerel OR herring OR tuna OR halibut OR seaweed OR anchov* OR sardine* OR (ropufa OR maxepa OR omacor OR efamed OR resq OR epagis OR almarin OR coromega OR lovaza OR vascepa OR icosapent AND ethyl) OR (fish AND consumption OR fish AND intake) OR fish NEAR/2 diet* OR Mediterranean NEAR/2 diet* OR (red AND blood AND cell OR phospholipid OR plasma AND fatty AND acid OR plasma OR phospholipid OR triacylglycerol OR cholesteryl OR ester OR adipos* OR fatty AND acid OR erythrocyte OR ghost OR platelet OR granulocyte OR neutrophil OR mononuclear OR ldl OR hdl AND (dha OR docosahexa?noic OR docosapenta?noic OR epa OR eicosapenta?noic OR sda OR linolenic OR stearidonic OR omega)) AND ('cardiovascular disease' OR atherosclero* OR arteriosclero* OR cardioprotect* OR (coronary OR heart AND disease* OR myocardial AND infarct*) OR (cerebrovascular AND accident) OR stroke.mp OR (transient AND ischemic AND attack) OR tia OR lipid* OR cholesterol OR 'low density lipoprotein' OR 'high density lipoprotein' OR hyperlipidemia* OR hypertriglyceridem* OR dyslipidemia* OR (blood AND pressure) OR (diastol* OR systol* OR mean AND arterial) OR hypertension OR hemorrhag* OR 'bleeding') AND (randomized AND controlled AND trial OR 'randomization' OR 'single blind procedure' OR 'double blind procedure' OR 'crossover procedure' OR 'placebo' OR rct OR (random* AND allocat*) OR (single AND blind*) OR (double AND blind*) OR (treble OR triple) NEAR/2 blind* OR (prospective AND study) OR 'clinical study' OR 'case control study' OR 'longitudinal study' OR 'retrospective study' OR 'prospective study' OR 'cohort analysis' OR cohort NEAR/2 (study OR studies) OR (case AND control NEAR/2 (study OR studies)) OR (follow AND up NEAR/2 (study OR studies)) OR observational NEAR/2 (study OR studies) OR (food AND frequency AND questionnaire*)) NOT ('abstract report' OR 'case study' OR 'case report') AND [humans]/lim AND [english]/lim AND [2000–2014]/py
Search2 fatty AND acids, AND essential OR essential AND fatty AND ('acids'/exp OR acids) OR (n AND 3 OR n3 OR 'n 3' AND (oil* OR pufa OR fatty AND acid* OR omega AND 3 OR omega3 OR 'omega 3')) OR docosahexa*noic OR docosapenta*noic OR eicosapenta*noic OR icosapent*enoic OR (alpha AND linolenic OR alphalinolenic OR 'alpha linolenic' OR linolenic AND acids) OR (linoleic AND acid) OR cervonic OR timnodonic OR stearidonic OR (flaxseed OR flax AND seed OR linseed OR rape AND seed OR rapeseed OR canola OR soy OR soybean OR walnut OR mustard AND seed OR perilla OR shiso OR menhaden OR fish AND oil*) OR (walnut* OR butternut* OR soybean* OR pumpkin AND seed*) OR (cod AND liver AND oil* OR codliver AND oil* OR marine AND oil* OR marine AND fat*) OR salmon OR mackerel OR herring OR tuna OR halibut OR seaweed OR anchov* OR sardine* OR (ropufa OR maxepa OR omacor OR efamed OR resq OR epagis OR almarin OR coromega OR lovaza OR vascepa OR icosapent AND ethyl) OR (fish AND consumption OR fish AND intake) OR fish NEAR/2 diet* OR mediterranean NEAR/2 diet* OR (red AND blood AND cell OR phospholipid OR plasma AND fatty AND acid OR plasma OR phospholipid OR triacylglycerol OR cholesteryl OR ester OR adipos* OR fatty AND acid OR erythrocyte OR ghost OR platelet OR granulocyte OR neutrophil OR mononuclear OR ldl OR hdl AND (dha OR docosahexa?noic OR docosapenta?noic OR epa OR eicosapenta?noic OR sda OR linolenic OR stearidonic OR omega)) AND ('cardiovascular disease' OR atherosclero* OR arteriosclero* OR cardioprotect* OR (coronary OR heart AND disease* OR myocardial AND infarct*) OR (cerebrovascular AND accident) OR stroke.mp OR (transient AND ischemic AND attack) OR tia OR lipid* OR cholesterol OR 'low density lipoprotein' OR 'high density lipoprotein' OR hyperlipidemia* OR hypertriglyceridem* OR dyslipidemia* OR (blood AND pressure) OR (diastol* OR systol* OR mean AND arterial) OR hypertension OR hemorrhag* OR 'bleeding') AND (randomized AND controlled AND trial OR 'randomization' OR 'single blind procedure' OR 'double blind procedure' OR 'crossover procedure' OR 'placebo' OR rct OR (random* AND allocat*) OR (single AND blind*) OR (double AND blind*) OR (treble OR triple) NEAR/2 blind* OR (prospective AND study) OR 'clinical study' OR 'case control study' OR 'longitudinal study' OR 'retrospective study' OR 'prospective study' OR 'cohort analysis' OR cohort NEAR/2 (study OR studies) OR (case AND control NEAR/2 (study OR studies)) OR (follow AND up NEAR/2 (study OR studies)) OR observational NEAR/2 (study OR studies) OR (food AND frequency AND questionnaire*)) NOT ('abstract report' OR 'case study' OR 'case report') AND [humans]/lim AND [english]/lim