# Abbreviations

AA: arachidonic acid
AE: adverse event
Abnl: abnormal
ACEi: angiotensin-converting enzyme inhibitor
ACS: acute coronary syndrome
AFib: atrial fibrillation
AHRQ: Agency for Healthcare Research and Quality
AIC: Akaike information criterion (estimation of fit of regression with spline)
ALA: alphalinolenic acid
ARB: angiotensin receptor blocker
BP: blood pressure
CABG: coronary arterybypass grafting
CHD: coronary heart disease
CHF: congestive heart failure
CI: confidence interval
CKD: chronic kidney disease
CMS: cardiometabolic syndrome
Ctrl: control
CVA: cerebrovascular accident (stroke)
CV: cardiovascular
CVD: cardiovascular disease
DBP: diastolic blood pressure
DHA: docosahexaenoic acid
DM: diabetes mellitus
DPA: docosapentaenoic acid
eGFR: epidermal growth factor receptor
EPA: eicosapentaenoic acid
E:D: EPA to DHA ratio
EPC: Evidence-based Practice Centers
ES: effect size
FA: fatty acid(s)
F/up: followup
FFQ: food frequency questionnaire
GI: gastrointestinal
HDL-c: high density lipoprotein cholesterol
HR: hazard ratio
HTN: hypertension
Int: intervention
LA: linoleic acid
LDL-c: low density lipoprotein cholesterol
LVEF: left ventricular ejection fraction
MACE: major adverse cardiovascular events
MAP: mean arterial blood pressure
MI: myocardial infarction
MUFA: monounsaturated fatty acid
n-3 FA: omega 3 fatty acid(s)
n6:3: omega-6 to omega-3 fatty acid ratio
n-6 FA: omega 6 fatty acid(s)
n/N: number with outcome/number analyzed
NA: not applicable
ND: no data
NYHA: New York Heart Association class
Obs: observational study
ODS: Office of Dietary Supplements
OR: odds ratio
PAD: peripheral artery disease
PCI: percutaneous coronary intervention
PCTA: percutaneous transluminal coronary angioplasty
PPFA: plasma polyunsaturated fatty acids
PUFA: polyunsaturated fatty acids
RBC: red blood cell
RCT: randomized controlled trial
RD: risk difference
RR: relative risk
SBP: systolic blood pressure
SCD: sudden cardiac death
SDA: stearidonic acid
SFA: saturated fatty acid
SoE: Strength of Evidence
TEP: Technical Expert Panel
Tg: triglycerides
TOO: task order officer