# Results

## Suicide Prevention Studies

The literature search identified 4,198 unique citations, of which 59 were eligible (Appendix D). Details on study characteristics are available in Appendix E. The 59 articles reported 47 studies. Study population size was highly variable: randomized controlled trials (RCTs) ranged in size from 32 to 2,100 people. Twenty-nine of the studies (62%) had 500 or fewer study participants. Very few (34.0%) of the prevention intervention studies we identified reported on outcomes longer than one year post-intervention. The percentage of female participants ranged from 15.4 percent13 to 100 percent.14 Race was reported in most (95%) of the studies. Reporting on race was often limited to only percentages of white participants and black participants, ranging from 8.1 percent white to 85 percent white (where reported). Reporting on education level was rare and, when included, referenced grade levels of participants during the study. Ten studies (21.3%) focused on special populations: military personnel,15-18 incarcerated individuals,13,14,19 victims of sexual trauma,20 people with major depressive disorder,21 and high-risk youth22 (Table 3; Appendix E). The 47 studies used a variety of interventions and approaches to prevention; many studies applied more than one approach: behavioral and skill building (19), medication or pharmaceutical (7), psychotherapy (4), education or education/skill building (12), policy (5), screening (5), other (9) (Table 3; Appendix E).

Table 3 Summary of intervention characteristics

Program or Study Name (If Applicable) Author, Year | Intervention Type/Purpose | Setting
Adolescent Suicide Risk Screening
King, 2012^23^ | Screening | Emergency department
Attachment-Based Family Therapy
Diamond, 2010^24^ | Psychotherapy, behavioral/skill building | Emergency department, primary care
Diamond, 2012^20^ | Psychotherapy, behavioral/skill building | Emergency department, primary care
CAMS‡
Jobes, 2012 15 | Psychotherapy | Primary care, emergency department, military base
Jobes, 2012^15^ | Psychotherapy | Primary care, emergency department, military base
C-CARE/CAST
Eggert, 2002^25^ | Behavioral/skill building | School
Randell, 2001^26^ | Behavioral/skill building | School
Thompson, 2001^22^ | Behavioral/skill building | School and home
Hooven, 2010^27^ | Behavioral/Sskill building, education
Communities That Care
Oesterle, 2015^28^ | Policy/legislation | Community-based
GLS
Garraza, 2015^19^ | Education/training/screening/infrastructure/crisis hotline/community partnerships (Garrett Lee Smith Memorial Suicide Prevention Program) | School/juvenile justice/community-based/primary care
Walrath, 2015^29^ | Screening, behavioral, policy changes, outreach, referral to mental health professionals, means restriction | NR^*^
Good Behavior Game
Wilcox, 2008^30^ | Behavioral/skill building, educational | School
HOPE Family Program/ HOPE Health Education Program
Lynn, 2014^31^ | Behavioral/skill building (HOPE Family Program) | Family housing shelters
National Treatment Improvement Evaluation Study
Ilgen, 2007^32^ | Substance abuse treatment | Primary care (outpatient and residential)
PGC
Thompson, 2000^33^ | Behavioral/skill building | School
Project Chrysalis
Brown, 2001 34 | Behavioral/skill building, education | School
Promoting Care
Hooven, 2012^35^ | Behavioral/skill building, education | School and home
SAFETY Program
Asarnow, 2015^36^ | Educational/skill building (SAFETY Cognitive-Behavioral Family Treatment Program) | Emergency department
Seattle Social Development Program
Hawkins, 2005^37^ | Educational/skill building (Seattle Social Development Project intervention) | School
SOS
Aseltine, 2004^38^ | Educational | School
Aseltine, 2007^39^ | Educational | School
Student Assistance Program
Biddle, 2014^40^ | Multiple strategies | School
Surviving the Teens Suicide Prevention and Depression Program
King, 2011^41^ | Behavioral/skill building, Education | School
Systemic Crisis Intervention Program
Gutstein, 1990^42^ | Behavioral/skill building | Primary care (outpatient)
TADS
March, 2007^43^ | Medication or pharmaceutical/Behavioral/Skill building (fluoxetine hydrochloride therapy and CBT) | Primary care/community-based
TADS, 2009^44^ | Medication or pharmaceutical/Behavioral/Skill building (fluoxetine hydrochloride therapy and CBT) | Primary care/community-based
Vitiello, 2009^45^ | Medication or pharmaceutical/Behavioral/Skill building (fluoxetine hydrochloride therapy and CBT) | Primary care/community-based
TADS- SOFTAD
Curry, 2011^46^ | Medication or pharmaceutical | Primary care/community-based
TASA
Brent, 2009^47^ | Medication or pharmaceutical/behavioral/skill building (psychotherapy and medication management) | Primary care
Vitiello, 2009^48^ | Medication or pharmaceutical/behavioral/skill building (psychotherapy and medication management) | Primary care
The Coping Cat Program
Wolk, 2015 49 | Behavioral/skill building (CBT) | Primary care
TORDIA
Asarnow, 2011^50^ | Medication or pharmaceutical (medication switch and CBT) | Primary care
Emslie, 2010^51^ | Medication or pharmaceutical (medication switch and CBT) | Primary care
Shamseddeen, 2011^52^ | Medication or pharmaceutical (medication switch and CBT) | Primary care
Woldu, 2011^53^ | Medication or pharmaceutical (medication switch and CBT) | Primary care
US Air Force Suicide Prevention
Knox, 2003^18^ | Educational | Military base
YST-1
King, 2006^54^ | Educational/skill building (psychoeducation targeted for support persons) | Primary care (inpatient)
YST-2
King, 2009^55^ | Educational/skill building (psychoeducation targeted for support persons) | Primary care (inpatient)
No named prevention program or trial
Anestis, 2015^56^ | Policy/Legislation | NR^*^ (50 U.S. States)
Asarnow, 2011^57^ | Behavioral/skill building (Family Intervention for Suicide Prevention) | Emergency department
Brown, 2005^58^ | Cognitive therapy | Emergency department
Collins, 2008 59 | Medication or pharmaceutical | Emergency department/primary care
Cooper, 2006 60 | Safety-net of mental health services | NR^*^ (acute care hospitals)
Farmer, 1996^13^ | Policy/legislation | Emergency department/prison
Fleegler, 2013^61^ | Policy/legislation | NR^*^ (50 U.S. States)
Gardner, 2010^62^ | Screening | Primary care
Huey, 2004^63^ | Behavioral/skill building (multisystemic therapy) | Emergency department
Kaminer, 2006^64^ | Aftercare | NR^*^ (outpatient)
Kennard, 2014^21^ | Medication or pharmaceutical and psychotherapy (medication management and CBT) | Primary care (outpatient)
Kerr, 2014^14^ | Behavioral/skill building (Multidimensional Treatment Foster Care) | Juvenile justice
Olfson, 2003^65^ | Medication and pharmaceutical | NR^*^ (county-level suicide rates)
Rathus, 2002^66^ | Psychotherapy and behavioral/skill building (Dialectical Behavior Therapy) | Primary care (outpatient)
Rotheram-Borus, 2000^67^ | Specialized emergency department (ED) care intervention | Emergency department
Rudd, 1996 68 | Behavioral/Skill building | Primary care (outpatient)
Segal, 1995^69^ | None provided (recommendation for continued intensive impatient treatment) | Emergency department
Spirito, 1992^70^ | Followup interviews | Emergency department/home
Warner, 2011^16^ | Screening | Primary care/military base
Wharff, 2012 71 | Behavioral/skill building (family-based crisis intervention) | Emergency department
Wingate, 2005^17^ | Behavioral/skill building | Primary care (inpatient and outpatient)/emergency department/military

* Study was not specific in regard to program setting, incorporating county, State, or regional data.

CAMS=The Collaborative Assessment and Management of Suicidality ; CARE=Care, Assess, Respond, Empower; CAST=Coping and Support Training; CATCH-IT=Competent Adulthood Transition With Cognitive Behavioral And Interpersonal Training; C-CARE=Counselors: Care, Assess, Respond, Empower; CBT=cognitive behavioral therapy; ED=emergency department; GLS=The Garrett Lee Smith Memorial Suicide Prevention Program; NASY=National Annenberg Survey of Youth; NR=not reported; PGC=Personal Growth Class; RCT=randomized controlled trial; SOFTADS=Survey of Outcomes Following Treatment for Adolescent Depression; SOS=Signs Of Suicide; TADS=Treatment for Adolescents with Depression Study; TASA=Treatment of Adolescent Suicide Attempters; TORDIA=Treatment of Resistant Depression in Adolescents; YST-1=Youth-Nominated Support Team for Suicidal Adolescents (Version 1); YST-2=Youth-Nominated Support Team for Suicidal Adolescents (Version 2)

## Data Systems

Our literature search, environmental scan, and targeted geographical searches identified 153 unique data systems (Figure 3; Appendix F). Our literature search identified seven unique data systems from the eligible articles of suicide prevention interventions and an additional 43 data systems from the articles screened at the full-text level.

Figure 3 Results of the search for data systems

Note: Reasons for exclusion: duplicate data system, did not meet one or more of the PICOTS (populations, interventions, comparisons, outcomes, timing, setting) elements (i.e., did not report outcome information)

Describes the flow of how data systems were identified (via systematic review, environmental scan, or targeted search) and there distillation to 153 data systems identified.

The environmental scan identified 80 unique data systems. Overall, 71 percent of the State and tribal community entities contacted replied with 23 unique data systems identified.

## Key Question 1 What national, State, and community data systems can be linked to existing data from suicide prevention interventions in order to add possible value for stakeholders, and what methods are available to link the data systems?

Of the 153 data systems we identified, we found that 89.5 percent can be readily acquired for free or for a fee and 74.5 percent can be downloaded from the Internet in an aggregated and anonymized format. Of the data systems available on Web sites, only 1.3 percent permitted an automated registration process to obtain the data while 79.1 percent required confirmation by a data manager. Data dictionaries were accessible for 47.7 percent of the data systems.

Of the data systems identified, 19.0 percent are used primarily for research, 11.1 percent for clinical care or operations, 29.4 percent for administrative services (such as for billing), and 52.3 percent for surveillance (some systems have multiple types of use). The geographic coverage of the data systems is as follows: 36.6 percent provide national-level data, 12.4 percent regional-level, 63.4 percent State-level, and 41.2 percent smaller than State-level (i.e., communities by zip code, county, census block, tribal boundaries, territory, or island) (some data systems provide coverage for more than one geographical unit) (Table 4). A few data systems were identified that are specifically designed with a focus on subgroups of interest, such as tribal communities (0.7%), LGBTQ populations (2%), active duty military service members (6.5%), incarcerated populations (3.3%), and primary school, secondary school, and university students (18.3%).

Table 4 Summary of data systems identified for Key Question 1

| Measure | Yes | No | N/A
Geographic Coverage | United States – national | 36.6% | 63.4% | 0.0%
Geographic Coverage | United States – regional (e.g., east coast) | 12.4% | 87.6% | 0.0%
Geographic Coverage | United States – State level (e.g., Maryland) | 63.4% | 36.6% | 0.0%
Geographic Coverage | United States – smaller than State level | 41.2% | 58.8% | 0.0%
Geographic Coverage | County | 32.0% | 67.3% | 0.7%
Geographic Coverage | Zip code | 15.0% | 84.3% | 0.7%
Geographic Coverage | Census block | 2.0% | 98.0% | 0.0%
Geographic Coverage | Tribal | 1.3% | 98.7% | 0.0%
Geographic Coverage | Territory | 0.7% | 99.3% | 0.0%
Geographic Coverage | Islands | 0.7% | 99.3% | 0.0%
Geographic Coverage | Other | 0.0% | 0.0% | 0.0%
Level of Information Available for This Data System | Data exist and can be acquired (free or for a fee) | 89.5% | 0.0% | 10.5%
Level of Information Available for This Data System | Data are publicly available and can be downloaded (e.g., PUF) | 74.5% | 21.6% | 3.9%
Level of Information Available for This Data System | Data can be acquired but requires an automated registration | 1.3% | 97.4% | 1.3%
Level of Information Available for This Data System | Data can be acquired if confirmed by a person (e.g., needs email communication) | 79.1% | 0.0% | 20.9%
Level of Information Available for This Data System | Data dictionary or code book is accessible | 47.7% | 52.3% | 0.0%
Data System's Primary Use | Research | 19.0% | 81.0% | 0.0%
Data System's Primary Use | Clinical care/operations | 11.1% | 88.9% | 0.0%
Data System's Primary Use | Administrative services (e.g., census) | 29.4% | 70.6% | 0.0%
Data System's Primary Use | Public health (e.g., surveillance) | 52.3% | 47.7% | 0.0%
Suicide Outcome(s) Included | Suicide ideation | 29.4% | 64.1% | 6.5%
Suicide Outcome(s) Included | Suicide attempt | 54.2% | 38.6% | 7.2%
Suicide Outcome(s) Included | Suicide completion | 70.6% | 25.5% | 3.9%

N/A=not enough information based on what was found to make a yes/no decision; PUF = publicly uploadable file

In regard to data granularity, patient-level data exists allowing for potential individual-level linkage for 96.7 percent of data systems identified; 2.6 percent of data systems only included aggregated data, allowing for ecological linkage to suicide prevention programs by demographic characteristics (59.5%), geographic region (56.2%), clinical specifications (42.5%), and entity type, such as an insurance company, health care provider, educational institution or employer (17.6%). Data sampling was used by 15.7 percent of the data systems identified.

Of the data systems identified, 29.4 percent included data on suicide ideation, 54.2 percent included data on suicide attempts, and 70.6 percent included data on suicide completion. The coverage by the identified data systems for intermediate and secondary outcomes of interest was as follows: 28.1 percent included psychiatric and substance abuse disorders, 38.6 percent included service utilization for psychiatric and substance abuse disorders, 11.8 percent included graduation rates, 5.9 percent included incarceration and arrests, 44.4 percent included violence perpetration and victimization, 10.5 percent included social support and social connectedness, and 39.2 percent included access to lethal means. The types of data systems identified were as follows: 18.3 percent were designed specifically to capture information about suicide, 41.8 percent death records, 43.8 percent health care provider records (EMRs), 47.7 percent population-based surveys, and 5.2 percent health insurance claims data. Of those data systems identified, 94.1 percent are ongoing with prospective data collection, whereas only 5.2 percent have partially stopped data collection. The average year of the start of data collection is 1994.

We classified the 153 data systems into three tiers to identify those that can be linked to existing data from suicide prevention interventions as “fairly accessible,” “potentially accessible,” and “more information needed.” These classifications were based on whether ‘individual level data’ or ‘aggregated data’ is offered through one of the following models: (1) the data are freely available on the Web site to download (e.g., public use file); (2) data access requires a registration process (often with no additional checks); (3) request is reviewed manually by a person/committee before access to the data is granted; and, (4) whether a data dictionary is available. Based on this classification, 123 data systems were identified as “fairly accessible” (66 of these have a data dictionary available), 20 data systems as “potentially accessible,” and “more information is needed” for 12 data systems (Appendix F).

## Key Question 2 Which statistical methods are reliable and valid for analyzing linked national, State, and community data systems and suicide prevention data to avoid misleading conclusions?

a. What are potential sources of bias for these statistical methods?
b. What are the advantages and disadvantages of these different methods?

Six studies reviewed linked to outcome data from external national, State, or community data systems (see Table 5). Three of these studies linked data at the individual level, using an individual linking variable such as social security number. Three of these studies linked data at an ecological level, using a variable such as zip code or county.

Table 5 Summary of analytic methods, data linkage, and data systems used in the prevention studies that linked to external data systems (n=6)

Author, Year | Analytic Method | Linking Level | Brief Results | Data System
Walrath, 2015^29^ | Sequential propensity scores; simple regression model | County | Counties that implemented training had significantly lower youth (10 to 24 years of age) suicide rates as compared with counties that did not obtain training. | SAMHSA-Funded Garrett Lee Smith Dataset; U.S. Census Bureau; Bureau of Labor Statistics
Gardner, 2010^62^ | Logistic regression | Individual | 14% of youth reported a suicidal thought in the previous month. | Nationwide children's hospital EHRs
Collins, 2008^59^ | Cox proportional hazards models | Individual | In comparison of mood stabilizers, divalproex was the most common mood stabilizer and demonstrated an increased risk for suicide attempts compared with lithium. | Oregon Medicaid data, Oregon vital statistics
Olfson, 2003^65^ | Adjusted linear regression models, t-tests | Region | Regional increase in the adolescent use of antidepressants was associated with a decrease in adolescent suicide attempts. | Pharmacy benefit management organization, CDC's national suicide mortality rates, U.S. Census Bureau, Area resource file
Farmer, 1996^13^ | Descriptive statistics | Individual | After a suicide prevention program was implemented, only one suicide was reported; 13 cases of suicide attempt required emergency medical attention. | Galveston County Jail records
Cooper, 2006^60^ | Logistic regression | County | Living in a county that offered a minimum safety-net of mental health services significantly reduced suicide risk. | Colorado Trauma Registry, U.S. Census Bureau

CDC=Center for Disease Control and Prevention; SAMSHA =Substance Abuse and Mental Health Services Administration; EHR=electronic health record

The studies conducted data analyses with individually-linked data systems using the following methods: logistic regression, Cox proportional hazards models, and simple descriptive statistics. These methods are generally considered appropriate for use with this type of data. The studies that conducted data analyses with ecologically-linked data used simple regression models (both logistic and multivariate) and t-tests. Regression methods can be appropriate for use with ecological data if they account for clustering with mixed effects models. The studies that used regression models did account for clustering within their models.

## Key Question 3 Which statistical methods are reliable and valid for understanding possible moderators in suicide prevention programs to improve targeting interventions to populations?

None of the six studies that linked to external data systems (Table 5) conducted statistical analyses to understand moderators of intervention impact. Twelve studies explored the effect of moderators in suicide prevention efforts; all moderation relationships were stated as a-priori hypotheses. Ten of these 12 studies used a form of regression, either linear or logistic, depending on the outcome of interest, and interaction terms to explore moderation (Table 6). This is an effective analytic technique to explore the effects of moderators on suicide prevention interventions. Researchers typically look for a significant interaction term followed by probes to determine whether the effect of the intervention significantly differs for chosen conditional values of the moderator.72 For example, Rotheram-Borus, et al.67 were interested in the interaction between the intervention program of interest and baseline psychiatric symptoms. Psychiatric symptoms were coded into a three-category variable: low, moderate, and high. An interaction term was created between symptom severity category and intervention status and included in the linear mixed regression model. This methodology is appropriate for the exploration of moderators in prevention or intervention effectiveness.

Table 6 Summary of moderator variables and analytic methods in studies that assessed effects of moderators (n=11)

Author, Year | Moderator Variables | Brief Results | Analytic Methods
Diamond, 2012^20^ | Sexual trauma | History of sexual trauma did not moderate treatment outcome for attachment-based family therapy. | Hierarchical generalized linear model
King, 2012^23^ | Receipt of public assistance, gender | Adolescents whose families did not receive public assistance had higher levels of suicide ideation if assigned to in-person followup. | ANOVAs and logistic regressions
King, 2009^55^ | History of multiple suicide attempts, gender | Youth-nominated support team intervention effects were moderated by a history of multiple suicide attempts, demonstrating more rapid decrease in ideation for those with multiple attempts. | Mixed effects models
Kaminer, 2006^64^ | Internalizing disorders, externalizing disorders, substance use disorders, suicide ideation | Results of the intervention did not significantly differ by gender, DISC internalizing disorders, DISC substance use disorders, and baseline SIQ scores. | General linear models
King, 2006^54^ | Gender | Adolescent girls who received the Youth-nominated support team intervention demonstrated greater decreases in self-reported suicide ideation as compared with girls who did not get the intervention. | Chi-square, Fisher's exact test
Wingate, 2005^17^ | Problem solving appraisal | Participants with poor problem solving appraisal at baseline responded better than participants with good problem solving appraisal. | Hierarchical multiple regression
Huey, 2004^63^ | Gender, age, ethnicity | Multisystemic therapy was more effective at reducing suicide attempts as compared with emergency hospitalization, this relationship varied by ethnicity, gender, and age. | Mixed effects growth models
Thompson, 2000^33^ | Gender | Personal control mediated the relationship between support resources and suicide risk behavior. | Hierarchical linear growth modeling
Rotheram-Borus, 2000^67^ | Psychiatric symptoms | The intervention had the greatest impact on maternal emotional distress and family cohesion among suicide attempters who were highly symptomatic. | Linear mixed effects regression model
Curry, 2011^46^ | Family income, depressive symptoms, cognitive distortions | Family income, depressive symptoms, and cognitive distortions all moderated the acute outcome of the TADS study. | Logistic regression
Shamseddeen, 2011^52^ | School difficulties | Lowest rates of response occurred among adolescents having school difficulties and ending treatment during the active school year. | Multivariate regression
Hawkins, 2005^37^ | Sex, poverty, ethnicity | Intervention effects significantly differ by gender but not by childhood poverty. White participants in the full intervention group showed more constructive engagement compared with those in the control group. | MANOVA

ANOVA=analysis of variance; DISC=The Diagnostoc Interview Scale for Children; MANOVA=Multivariate Analysis of Variance; SIQ: Suicidal Ideation Questionnaire

Only 12 studies explored moderation effects; much of the research included is primarily focused on the main effects of interventions, and treatment effect heterogeneity is not assessed.