# Methods

We identified suicide prevention intervention studies and relevant data systems on suicide prevention (see Table 2) in three parallel phases. In the first phase, we completed a systematic review of published literature to identify suicide prevention studies and existing data systems. The results of this phase informed Key Questions 1, 2, and 3. In the second phase, we completed an environmental scan to identify suicide data systems not reported in published literature. This phase further informed Key Question 1. In the last phase, we performed a targeted search to identify data systems used in selected States, cities, or communities. This phase expanded the results for Key Question 1.

Table 2 Overall search methodology to address Key Questions 1, 2, and 3^*^

Phase^†^ | Key Question | Search Criteria^‡^ | Search Engines or Data Sources | Number of Raters/Coders | Suicide Prevention Studies Identification | Data System Identification | Statistical Method Identification | Moderator Identification
1. Systematic Literature Review | KQ1 | PICOTS^§^ | - PubMed; - Cochrane; - Campbell; - CINAHL; - PsycINFO; - ERIC | 2 | Yes | Yes | - | -
1. Systematic Literature Review | KQ2 | PICOTS^§^ | - PubMed; - Cochrane; - Campbell; - CINAHL; - PsycINFO; - ERIC | 2 | Yes | - | Yes | -
1. Systematic Literature Review | KQ3 | PICOTS^§^ | - PubMed; - Cochrane; - Campbell; - CINAHL; - PsycINFO; - ERIC | 2 | Yes | - | - | Yes
2. Environmental Scan (Web) | KQ1 | PICOTS^§^ | - Google; - Yahoo; - Bing; - SPRC; - AFSP; - AAS | 1-2 | - | Yes | - | -
3. Targeted Search║ | KQ1 | PICOTS^§^ + Location | Selected State, city, and local government personnel | 1-2 | - | Yes | - | -

* KQ4 is not included in this table because it reflects a synthesis of opportunities and challenges based on the results of KQ1-3.

‡ Inclusion and exclusion criteria are the same for all searches.

† All phases of the search method required that included studies and data systems included suicide prevention interventions.

§ See Table 1 for the full PICOTS description.

║ Six States, two cities, and one local community were selected based on suicide rates, geographic location, and the presence of active SAMHSA (Substance Abuse and Mental Health Services Administration) or GLS (Garrett Lee Smith Memorial Suicide Prevention Program) support. Terms representing these States, cities, or local communities were added to the PICOTS terms.

AAS=American Association of Suicidology; AFSP=American Foundation for Suicide Prevention; KQ=Key Question; PICOTS=Population, Interventions, Comparators, Outcomes, Timing, Setting; SPRC=Suicide Prevention Resource Center

## Suicide Prevention Studies: Systematic Review

We searched PubMed, The Cochrane Library, Campbell Collaboration Library of Systematic Reviews, Cumulative Index to Nursing and Allied Health Literature (CINAHL), PsycINFO and Education Resources Information Center (ERIC) from January 1, 1990 to December 21, 2015. We developed a search strategy for PubMed based on medical subject headings (MeSH) and title and abstract terms from eligible articles we identified a priori. We used this search to develop strategies for the other search engines (see Appendix B).

We uploaded the articles into DistillerSR (Evidence Partners, Ottawa, Ontario, Canada), a Web-based service for systematic review and data management. We used DistillerSR to track the screening process and results.

The inclusion and exclusion criteria for the systematic review were derived from the PICOTS (see Table 1). Specific exclusion criteria for title and abstract screening and full-text screening were the following: not a study of humans only, does not include data on individuals between the ages of 0 and 25 years, does not include an intervention of interest, does not include a primary outcome of interest, takes place outside of the United States, meeting abstract only, and no original data. We did not limit study inclusion by study population size or study design. Studies published prior to 1990 were not included because, according to the NAASP, suicide became a central issue in the United States in the mid-1990s with the Surgeon General's Call to Action to Prevent Suicide, published in 1999.^8^ The amount of abstractable data is significantly limited prior to 1990.

Two reviewers independently screened titles and abstracts first, and then full-text articles. Disagreements about article eligibility that could not be resolved by the two reviewers were resolved by the domain experts on the team. We abstracted data on study characteristics, participant characteristics, intervention characteristics, and suicide outcomes to Microsoft Excel tables. As applicable, we also abstracted the primary analytic method used by the study to link data systems, statistical tests used in the study, and analyses performed. We abstracted variables used in the analyses, as well as those controlled for as covariates. Additionally, we identified and abstracted data system information (e.g., location of database) and how the data were linked to other sources.

A trained research assistant abstracted the data and another team member checked it. In the case of a disagreement, yet another team member reviewed the abstracted data, and the issue was resolved by consensus. If consensus was not attainable for a specific case, it was discussed by the full review team and resolved by majority vote. The same process was used for all data abstraction that was a part of this project. Abstracted data will be uploaded to the Systematic Review Data Repository™ (SRDR), a Web-based data repository, at completion of the project.

## Data Systems

We conducted three phases of searches for data systems (described below). For results from these phases, two independent reviewers determined whether the identified data systems (i) met the PICOTS elements and (ii) fulfilled the minimum requirements of a data system that can be useful for linkage to suicide prevention studies. We excluded data systems that did not meet all of these requirements:

a. Data system is still in existence and underlying data are available and accessible in digital format (e.g., datasets can be downloaded from a current website with or without permission or are available in another format);
b. Data system can be shared and acquired by others for research purposes (e.g., it has a public or transferable license that allows the data to be used for research purposes);
c. Data system collects and contains at least one of the primary outcomes; and,
d. Data system is not a duplicate of another data system already included in the project.

The process of data abstraction for the data systems was the same as for the systematic review. We abstracted data about the PICOTS (see Table 1), such as study and participant characteristics when they were present, as well as details about the data systems and statistical methods. The coding and classification schema for the data systems was adapted and modified from a framework previously developed to evaluate the quality of community-based data sources.9 The coding schema can be found in Appendix C. The process was limited to the information that could be extracted from information found through online searches. Acquiring data dictionaries or downloading and analyzing the data sources within each of these data systems, if they were not available on the Internet, was considered to be out of the scope of this project.

### Phase 1 Systematic Literature Search

We scanned all eligible suicide prevention studies identified in the search for data systems. We also checked articles excluded during the full-text screen that had been tagged as having a database or data systems. These databases were then re-reviewed for inclusion during Phase 2 of the methodology. We sought additional information about the data systems identified from the systematic review using the following methods: searching the Internet for additional information about the data systems; finding the data dictionaries associated with the data system, if available; downloading a sample data set from the data system, if available; reviewing the data sources used in the data system; and, searching for additional reports that may have described the data system in more detail.

### Phase 2 Environmental Scan

To identify additional data systems on suicide prevention that may not be reported in the published literature, we conducted an environmental scan of grey literature on suicide prevention programs among youth. We searched the Web for pre-prints, preliminary progress and advanced reports, technical reports, statistical reports, memoranda, state-of-the-art reports, market research reports, theses, conference proceedings, technical specifications and standards, non-commercial translations, bibliographies, technical and commercial documentation, and official documents not published commercially (primarily government reports and documents).10

We did not limit the environmental scan to a specific type of document retrieved from the Web (i.e., the document could be an HTML webpage or a document in a downloadable format.) We used the PICOTS (Table 1) to determine whether a specific page/document was applicable. We required the presence of the population of interest (P), one of the primary outcomes (O), timing (T), and setting (S); however, Intervention and Comparison elements of PICOTS were not required.

The search terms and eligibility criteria used in the systematic review were also used for the environmental scan (see Appendix B). We used the advanced search functions of three search engines [Google, Yahoo, and Bing (Microsoft)] to execute the search. These search engines collectively represent 97 percent of the U.S. online search market.11 Owing to the extensive list of results returned by these search engines, only the first 100 retrieved documents from each database were considered. This limitation was also based on the finding that the precision of search engine results often reduces considerably after the first few dozen retrievals.12 To ensure a high recall or precision rate, the review team examined every 10 results ranked between the 100^th^ to the 300^th^ results of these search engines. If at least one-third of these results were determined to be relevant to this review, we expanded the environmental scan to include the first 300 results from all three search engines. We excluded from the review duplicate results across the search engines and data systems that were already identified by the systematic review.

We also conducted an exploration of specific government, foundation, and professional association Web sites (national/Federal, State-level, and local/city/community-level): American Foundation for Suicide Prevention (AFSP), the American Association of Suicidology (AAS), and the Suicide Prevention Resource Center (SPRC) to identify data systems which could be linked to prevention programs.

### Phase 3 Targeted Search

We conducted a targeted search for data systems providing information on suicide prevention in six States (CA, DE, OR, IL, MD and WI), two cities (Baltimore, MD and Wilmington, DE), and one tribal community (The Menominee Reservation in Wisconsin). It was beyond the scope of this project to complete a more comprehensive review across all States or major cities. We sought data systems that provided information about our primary outcomes (i.e., suicide ideation, suicide attempt, and suicide) (see Figure 2) and were maintained by a State, city, or community-level entity.

Figure 2 Suicide rates among persons aged 10–24 years by State -- United States, 2012-13

Note: All races, ethnicities, sexes, and ages; Annualized crude rate for U.S is 11.59; Map generated by CDC Web-based Injury Statistics Query and Reporting System (WISQARS) .Source: CDC vital statistics—WISQARS.

United States among persons aged 10-24 years by state—United States, 2012-13 (US average 8.1 per 100,000). Represents the US by state and identifies suicide rate per 100,000 population. IncludesAll races, ethnicities, sexes, and ages; Annualized crude rate for U.S is 11.59; Map generated by CDC WISQARS.Source: CDC vital statistics—WISQARS.

The six States were selected based on the following criteria: (1) the State has an active Substance Abuse and Mental Health Services Administration (SAMHSA) Garrett Lee Smith Memorial Suicide Prevention Program State youth suicide prevention grant that should facilitate the acquisition of information about suicide data sources (as SAMHSA has provided resources to facilitate and encourage State grantees to use data systems in their local evaluation procedures so data systems including suicide ideation, suicide attempt and suicide should be familiar to the State's contacts); (2) geographic proximity; matched pairs of States with a suicide rate lower and higher than the national crude average rate of suicide in 2010-2014 (8.4 per 100,000 population among those 10-25 years of age1); and, to some extent, (3) familiarity of the research team experts with the data systems of those States. All of the six States match the first and second criteria (see Figure 2). In regards to the second criterion, in the Pacific region, Oregon has a higher suicide rate (10.9/100k) while California has a lower suicide rate (5.9/100k); in the Midwest region, Wisconsin has a higher suicide rate (10.4/100k) while Illinois has a lower suicide rate (6.9/100k); and, finally, in the Mid-Atlantic region, Delaware has a higher suicide rate (8.6/100k) while Maryland has a lower suicide rate (6.7/100k).

We contacted (via email and phone) individuals in each selected State, city, and community to request information on State- and community-level data sources/systems that include suicide ideation, suicide attempt, and suicide among those under 26 years of age. The individuals were the designated contacts provided for State suicide prevention efforts, such as the Garrett Lee Smith Suicide Prevention program, and members of State, city, and community suicide prevention commissions or coalitions.