# Introduction

Despite advances in the diagnosis and treatment of major mental disorders and increases in funding for suicide prevention, annual suicide rates in the United States for those in the 10-14, 15-19, and 20-24 age groups have increased since 2007.^1^ In 2014, suicide was the second leading cause of death among people between the ages of 15 to 19 and 20 to 29.^2^ According to estimates from the national Youth Risk Behavior Surveillance System at the Centers for Disease Control and Prevention (CDC), each year well over one million high school students are treated by a nurse or doctor for a suicide attempt.3

The National Action Alliance for Suicide Prevention (NAASP) (see Appendix A for a list of acronyms), the public-private partnership advancing the National Strategy for Suicide Prevention, developed a suicide prevention research agenda focusing on interventions with the potential to reduce morbidity (attempts) and mortality (deaths) by at least 20 percent in 5 years and at least 40 percent in 10 years. Specifically, the NAASP Task Force prioritized the prevention of “the emergence of suicidal behavior by developing and delivering the most effective prevention programs to build resilience and reduce risk in broad-based populations.”3

However, identifying the most effective prevention interventions is challenging. Several issues contribute to make the determination of the impact of suicide prevention interventions difficult: (1) suicide is a rare outcome, requiring large studies to demonstrate an intervention effect; (2) misclassification and under-reporting of suicide and suicide attempts occur, owing to stigma and other issues; (3) there is no single, comprehensive, national system to document the scope of non-fatal suicide events; (4) interventions are often complex or “bundled” making it difficult to know which components are responsible for outcomes; and (5) the nature of populations at risk and available interventions require the use of quasi-experimental designs and “natural experiments” to evaluate prevention efforts. In addition, under the current funding structure of 3- to 5-year grant cycles, it is difficult to evaluate the longer-term impact of prevention interventions, especially those directed as primary prevention efforts, which can occur years before the peak period of risk for suicidal behaviors in young adulthood.

Thus, several unanswered questions remain regarding the effectiveness of youth suicide prevention efforts. Leveraging existing data from suicide prevention interventions may help to address these questions. National, State, and community data systems could be linked to existing data from suicide prevention efforts in order to study the longer-term and broader intervention impact. Data systems (a system that includes the collection of data, such as in a database, as well as the information technology infrastructure to maintain and operate the system) exist for purposes of surveillance of suicidal behaviors, for medical service billing, and for administrative purposes. The linkage of existing prevention intervention data to suicidal behavior outcomes could add value for stakeholders. The rapid expansion of electronic health record (EHR) systems and patient registries has created an exceptional opportunity for data linkage.4 The emergence of State All Payer Claims Databases (APCD) could also significantly facilitate data linkages. APCDs are large-scale databases that systematically collect medical claims, pharmacy claims, and eligibility and provider files from private and public payers. In addition, several States now have established Health Information Exchanges (HIE) that merge health care data from multiple health care systems. As mentioned in NOT-MH-14-015 [Data Sharing Expectations for National Institute of Mental Health (NIMH)-funded Clinical Trials], the widespread data sharing by research communities adds significant value to research and accelerates the pace of discovery.5

In the field of suicide prevention, the linking of existing data has not yet been standardized across studies. This is likely due to a number of issues such as cost, feasibility of accessing data systems, interoperability challenges, and issues of sharing protected health information (PHI). Direct data linkage on an individual-person level may require identifying information which is protected by the Health Insurance Portability and Accountability Act (HIPAA) and also, therefore, explicit informed consent.

## Scope of the Project

The aim of the project was to provide an objective description of the state of the science on data linkage strategies and analytic approaches in suicide prevention research, as well as a systematic summary of ongoing research limitations, barriers, challenges, gaps, and opportunities for future data linkage approaches to enhance suicide prevention efforts to serve as the foundation for a National Institutes of Health (NIH) Pathway to Prevention workshop. This project studied data linkage and systems but did not evaluate or compare effectiveness of suicide prevention interventions. We focused on children, youth, and young adults ages 0-25, which spans the age range from when suicide is relatively rare, but when primary preventive efforts may be effective, through adolescence and young adulthood, when suicide rates precipitously increase. We considered all socio-ecologic levels of interventions (individual, community, and policy-level), primary promotion of mental wellness as well as interventions targeting suicidal ideation, attempts, and suicide.

Our project sought to address the following Key Questions (KQs):

KQ1 What national, State, and community data systems can be linked to existing data from suicide prevention interventions in order to add possible value for stakeholders, and what methods are available to link the data systems?
KQ2 Which statistical methods are reliable and valid for analyzing linked - data to avoid misleading conclusions?
  a. What are potential sources of bias for these statistical methods?
  b. What are the advantages and disadvantages of these different methods?
KQ3 Which statistical methods are reliable and valid for understanding possible moderators in suicide prevention programs to improve targeting interventions to populations?
KQ4 Given the current state of research, what types of methodological/analytic advances would promote further evaluation of youth suicide prevention efforts (e.g., new approaches to data linkage, increased use of common data elements, approaches to intervention harmonization) and facilitate intervention selection and implementation decisions by local community and State-level policymakers?

## PICOTS

Table 1 describes the inclusion criteria (PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, Setting) applied to identify studies of suicide prevention interventions. We used the same criteria to identify data systems providing suicide-related outcomes, except that a specific intervention was not required (i.e., I and C not required for data systems).

Table 1 PICOTS description of inclusion criteria for suicide prevention studies and data systems

[underlined: P]opulation(s) | Received intervention: ages 0-25; (longitudinal follow-up past age 25 is acceptable).
[underlined: I]ntervention(s) (used for studies) | Behavioral, community, clinical/medical, policy level including studies promoting wellness targeting suicide ideation, suicide attempt, and suicide, or any combination of these interventions and outcomes.
[underlined: C]omparison(s) (used for studies) | Any intervention (including usual care).
[underlined: O]utcome(s) (the primary and intermediate outcomes) | Primary outcome of interest:; - Suicide ideation,^*^ reported within 12 months of data collection; - Suicide attempt, any time point post intervention; - Suicide, any time point post intervention; Intermediate outcomes (if primary outcome is present), at any time point post intervention:; - Psychiatric and substance abuse disorders; - Service use (e.g. emergency department visit) for psychiatric/substance abuse disorders; - Graduation rates; - Incarceration rates; - Violence (both perpetrator and victim); - Social support and connectedness; - Access to lethal means; All outcomes were limited to standardized measures.
[underlined: T]iming | Publication date: 1990 or later.
[underlined: S]etting | Studies taking place in the United States only: Schools, home, primary care, emergency department, military bases, Indian reservations, juvenile justice systems, child welfare systems, suicide hotlines, other community settings.

* Suicide ideation reported over the last 12 months reduces the potential for recall bias and provides more relevant information for current prevention and intervention.6, 7

## Analytic Framework

Figure 1 depicts the Key Questions illustrating how data, in populations of people from 0 to 25 years of age, from suicide prevention interventions (including behavioral, community, clinical/medical, and policy level) can be linked with national, community, or State data systems. Through statistical methods, these linked data can be analyzed to study the broader or longer-term impact of suicide prevention interventions. The study and identification of moderators of intervention impact (e.g., gender, race and ethnicity, LGBTQ (lesbian, gay, bi-sexual, transgender, queer) status, psychopathology status, trauma history, social connectedness, or social support) could suggest which individuals or subpopulations would most benefit from specific suicide prevention interventions. Studying moderators in linked data may be an efficient and cost-effective way of developing more personalized or community-informed prevention efforts.

Figure 1 Analytic framework for suicide prevention

ED = Emergency Department; KQ = Key Question; LGBTQ: Lesbian, Gay, Bisexual, Transgender, and Queer

Describes the population of interest (0 to 25 years old), how suicide prevention programs can be linked to national, community, or state data systems to address KQ1. Describes then that linked data should be assessed as reliable and valid by analyzing the data (KQ2) and assessing whether moderators are assessed (KQ3). A description of primary outcomes follows: Suicidal ideation, suicide attempt, or suicide completion; along with intermediate outcomes: psychiatric and substance abuse disorders, graduation rates, incarceration rates, violence, social support and connectedness, access to lethal means, and service use.