# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Julie Cerel, Ph.D.^*^
  University of Kentucky
  Lexington, KY
- Nicole Gibson, M.S.W.
  American Foundation for Suicide Prevention
  New York, NY
- Jill Harkavy-Friedman, Ph.D.^*^
  American Foundation for Suicide Prevention
  New York, NY
- Katherine Masyn, Ph.D.
  Georgia State University School of Public Health
  Atlanta, GA
- Victor Schwartz, M.D.^*^
  The Jed Foundation
  New York, NY
- Daniel Stein, B.A., M.B.A.
  Stewards of Change
  Huntington, NY
- Sharon Strouse, M.A., A.T.R.-B.C, L.C.P.A.T.^*^
  The Kristin Rita Strouse Foundation
  Baltimore, MD
- Gary Wynn, M.D.^*^
  Uniformed Services University of the Health Sciences
  Bethesda, MD

* Provided input on Draft Report.