# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ryoko Susukida and Fardad Gharghabi. We also thank Jeanette Edelstein for her assistance with this report.