# Discussion

## Key Findings

- A minority of community, State, and national datasets are currently usable for linkage: 121 of the 153 data systems we identified are fairly accessible, but only 66 of these have a data dictionary available.
- Most linkable datasets have outcomes related to suicide; fewer datasets include suicide ideation and suicide attempts.
- Most of the potentially linkable datasets offer the possibility of linkage at the individual level, but ethical or legal barriers may prohibit linkage at this level.
- Few datasets allow for the detailed study of particular high-risk populations, though variables indicating membership in one of those populations are widely available.
- Lack of readily available codebooks and data dictionaries for datasets limits ready access and the conclusions that can be drawn about the potential utility of linkage.
- Lack of adherence to a standard set of data elements in suicide data systems and prevention studies is a barrier that reduces the potential utility of linkage.
- Of the six studies that linked prevention intervention data with external data systems, three used ecological-level linking and three used individual-level linking. The methods used for data analysis were appropriate.
- Of the six studies that linked prevention intervention data with external data systems, all focused on intervention main effects. None assessed for treatment effect heterogeneity or the impact of moderators. Only 12 studies explored moderation effects.

Data systems are highly variable in terms of geographic reach and the inclusion of data about subpopulations. Of the 153 data systems identified, 36.6 percent are national and 41.2 percent have geographic coverage of areas smaller than a State. All 50 U.S. States are represented by at least one data system, usually the State's vital statistics data. Some States have multiple data systems for possible linkage to prevention programs. For the majority of these sources (89.5%), the data are potentially available for free or for a fee; however, of those, a data dictionary or codebook is readily accessible online for only 47.7 percent. Coverage of special populations at higher risk for suicide attempt and suicide is limited: only one of the systems identified is focused on Native American populations and only 2 percent are specifically focused on LGBTQ populations. Although few data systems allow for the comprehensive study of subpopulations at increased risk for suicide, variables indicating membership in one of those populations are available in 37.9 percent of the data systems.

Some data systems may be more useful to linkage efforts than others, depending on what variables the systems track. Most linkable data systems include suicide as an outcome; however, very large prevention studies are needed for sufficient statistical power to detect a difference in suicide death between intervention groups or over time. Many of the prevention studies identified had small sample sizes. Data systems including suicide ideation and attempts are less common, although the use of systems that include them may be more useful for prevention studies, as these variables are more prevalent than suicide and also have actionable outcomes (i.e. intervention could be initiated if someone at high risk for suicide were identified.) More than 94 percent of the data systems we identified appear to be updated on an ongoing basis, increasing the likelihood that linkage would be useful; however, information on data lags or completeness within the sources we located is not available.

Linking to external data systems could allow for longer-term assessment of suicide prevention interventions yet data system linkage is under-utilized in suicide prevention studies. While we identified 153 unique data systems, we found only six studies that included assessment of outcomes by linking their prevention data to external data systems at the individual or ecological level. The majority of the prevention studies identified have the capability to link to medical record data or mortality data, with patient-level consent. Because hospitals routinely track people who were treated for suicidal behaviors, the expansion of the electronic medical record could make accessing those data much easier. One study we identified29 showed that suicide prevention programs within geographic boundaries (e.g., counties) can be linked in aggregate or at an ecological level to suicide mortality data to study suicide prevention program impact before and after implementation. In this study, the authors compared data in counties with SAMHSA GLS youth suicide prevention programs to counties without SAMHSA GLS youth suicide prevention programs by linking to suicide mortality data at the county level. Their goal was to examine whether a reduction in youth suicide mortality that could be reasonably attributed to a GLS program occurred between 2007 and 2010. Several existing prevention programs could be enhanced, at low cost, by this type of linkage to data systems.

Of the six studies that linked with external data systems, three used ecological linking methodology and three used individual linking methodology. The analysis methods appropriately handled the different types of data. The bulk of the studies focused on the main effects of interventions and did not assess treatment effect heterogeneity, as only 11 of the 47 studies explored moderation effects.

## Findings in Relationship to What Is Already Known

Recently, a resource was published by the Data and Surveillance Task Force (DSTF) of the NAASP, which had been charged with making recommendations for improving national data systems on suicidal behaviors.73 The DSTF report listed suicide data systems, identifying 28 such systems (26 of which were eligible for inclusion in our project). The DSTF also made several recommendations to improve existing data systems:

1. Coding manuals and national surveys should adopt the use of standard language and definitions. For example, public and private organizations should adopt and promote the use of standard definitions such as those described in the CDC's Self-Directed Violence Surveillance Uniform Definitions and Recommended Data Elements;74
2. Suicide data systems should add missing key variables or data elements (e.g., socio-demographics, mechanism of injury) to existing nonfatal data systems to enhance their usefulness;
3. Medical records should include external cause coding (a data element needed to identify suicide attempts) as a requirement for reimbursement by insurance carriers;
4. Systems should capture “real-time” information on hospital emergency visits to improve the monitoring of trends in suicidal behavior;
5. All States should be encouraged to include nonfatal suicidal behavior (suicide attempts) by youth 12 to 17 years of age as a health condition to be reported to the State health department.

Our findings confirm the importance of these five points in addressing the need to make suicide data systems more useful. Our work builds on this, adding information on linkage of suicide data systems to suicide prevention intervention data to study the extended value of the suicide prevention efforts. To date, this has been a missed opportunity in the field of suicide prevention.

## Limitations of the Systematic Review Process

Our ability to determine which prevention studies might be linked to data systems was limited by the lack of available codebooks or data dictionaries outlining specifics about the available data sets. Some of the data dictionaries are available online (48%); however, when we contacted named contact people for each of the other data systems to request information about a data dictionary or codebook, we received no responses.

We were not able to assess data quality for the data systems identified. Only about half of the identified data systems are suicide-specific or had as their primary purpose the collection of data about suicide. The rest of the systems we identified were developed for other purposes (for example, hospital discharge data that happens to include suicide as an admitting or discharge diagnosis). We did not include some data systems, including Behavioral Risk Factors Surveillance System (BRFSS) and crime reports, because they do not have primary suicide outcomes; however, these might be used by other researchers to assess impact on behaviors that are highly correlated with suicidal behavior, including drug overdoses.

## Limitations of the Data Systems

Although linkage is possible, serious inadequacies exist in the quality of available suicide mortality and morbidity data: (1) the definitions of suicidal behavior vary greatly; (2) suicide is a rare outcome, so it is challenging to detect an intervention impact on suicide mortality without large studies (up to a million person years); (3) misclassification and under-reporting of suicide and suicide attempt as outcomes due to stigma, lack of information to confirm suicide intent was present, and other issues; (4) there is no single, comprehensive, national system to document the scope of non-fatal suicide attempts. There is regional variation in how suicide is investigated and coded and how people making a determination of suicide are trained. Rockett et al.75 note that variation in coding in the United States appears to be partially an artifact of geographic region and partially a degree of toxicological assessment in the case ascertainment process. Variation in classification could be driven by sociocultural or political factors (i.e., stigma), economic factors, or forensic factors (i.e., lack of training of providers to elicit the information needed). However, as pointed out by the CDC, the quality of the data on nonfatal suicidal behavior is even more problematic than that of suicides.74

According to the DSTF of the NAASP,76 the data systems currently used to estimate trends in suicidal behavior were not designed solely to address this subject. In these data systems, questions specific to suicidal behavior are often limited and the data systems may have lesser or variable quality in terms of ascertaining suicide morbidity and mortality as outcomes.

The CDC document Self-directed Violence Surveillance: Uniform Definitions and Recommended Data Elements addresses definitional inconsistencies as well as common data elements to promote and improve consistency of surveillance.74 Although the lack of readily available codebooks and data dictionaries limits our ability to say which databases are useful, only the National Violent Death Reporting System (NVDRS) and individual State versions of it adhere to the CDC common data dictionary for suicide databases.74 The lack of adherence to a standard set of data elements in suicide registries and studies is a barrier to linkage and reduces the potential utility of linkage.

Hospital and International Classification of Diseases (ICD) codes for self-harm are not necessarily suicide attempts; this is an important limitation. Diagnoses may be underreported during hospitalizations or physician visits. The same underlying condition may also be coded in different ways, depending on the clinical circumstances. Definitions of suicide-related constructs should have validity and reliability, but not all behaviors in the CDC Self-Directed Violence Surveillance have demonstrated reliability, validity, and utility. Suicidal behaviors recorded in hospital visits and suicide deaths reflected in mortality data typically reflect only the ‘tip of the iceberg’ of suicidal events.

## Future Research Needs and Opportunities

### Potential Benefit of Data Linkage

There are challenges in the United States related to financing the infrastructure required to sustain large-scale, coordinated suicide prevention efforts. Suicide prevention programs have limited ability to study long-term outcomes under the current funding structure. Our results show that longer-term results could be obtained by linkage of prevention efforts to existing data systems.

Linkage to accessible, current surveillance data could help to address the lack of studies testing the impact of early intervention on risk for suicide attempt and suicide.76 Primary prevention approaches delivered in early development require extended followup periods to track populations through the period of risk onset for suicidal thoughts and behaviors. Randomized trials of prevention programs conducted in early childhood have reported reduced occurrence and severity of mental, emotional, and behavioral problems that increase risk for suicidal behavior later in life (e.g., aggression, depression, substance use, and deviant peer associations);77,78,79 however, with the exception of Wilcox, et al., (2008)30 the impact of these programs on reducing suicidal behaviors is unknown at present because evaluators of these interventions have rarely followed their cohorts into the peak age of risk for suicide attempt and suicide and often did not include suicidal behavior in their outcome measures. Also, these interventions were often directed at early development, many years before suicidal thoughts and behaviors typically occur. The Wilcox, et al. (2008)30 study allowed for decades of longitudinal followup which may no longer be possible in the current research funding climate.

Aside from individual studies of interventions, there are several ongoing national initiatives in the United States targeting key risk factors for suicide, such as the National Child Traumatic Stress Network and Project LAUNCH (Linking Actions for Unmet Needs in Children's Health). These initiatives, and others, represent large investments by the Federal Government with broad national reach and the potential to impact suicide morbidity and mortality, which could be studied by data linkage. Linkage of these prevention data to systems, such as State HIE and the restricted-access NVDRS, would provide the ability to access individual-level quantitative data, as well as incident narrative reports on all suicide decedents. Currently, the NVDRS is available in only 32 States, but it could be expanded to all States. These data are potentially available for linking with other external data systems, if coordinated with State public health departments.

### Barriers to Data Linkage

There are several barriers or limitations suicide prevention scientists could face regarding the linkage of prevention data to data systems: the adequate ascertainment of those affected by suicide ideation and attempts; costs associated with access to the National Death Index (NDI) and other data systems; sizeable interoperability challenges on a national level, even for routine sharing of clinical data; the lack of adequate access to data dictionaries; and, the possibility that one data system may not have all the outcomes of interest to preventive studies and the consequent need to link to multiple data systems for a more complete picture of outcomes.

Suicide prevention efforts could be sustained by communities after grant or contract funding for suicide prevention programs end; however, there are few resources to sustain the assessment of study outcomes. With minimal resources, existing data systems could be accessed by service systems or public health agencies to assess the impact of suicide prevention activities. Ideally, this would be a bi-directional process whereby those agencies could also use data systems to proactively identify individuals, communities, or subgroups at risk for suicide to whom they could direct outreach and interventions.

There was a lack of studies identified in the literature review addressing the reduction of access to lethal means as a suicide prevention strategy, although many other countries have reduced their suicide rates this way.80 Means restriction approaches include firearm safety, construction of barriers at jumping sites, detoxification of domestic gas, improvements in the use of catalytic converters in motor vehicles, restrictions on pesticides, reduction of lethality or toxicity of prescriptions, use of lower-toxicity antidepressants, change in packaging of medications to blister packs, and restriction of sales of lethal hypnotics (i.e. barbiturates). Means restriction is the universal approach with the strongest and most consistent evidence of preventing suicide.56, 61, 81 This approach typically involves linkage to mortality data to study the impact of changes in legislation at the State level.

Because many of the prevention studies identified in the review had small sample sizes, and large sample sizes are needed to find an intervention impact on suicide attempt or suicide, intervention harmonization approaches could be beneficial. Intervention harmonization could help to identify who could benefit from different youth suicide prevention options across subpopulations and provide for personalized and contextualized interventions. Finally, the linkage of suicide morbidity and mortality data to the Collaborative Data Synthesis for Adolescent Depression Trials (R01MH040859), which has combined de-identified data from over 30 prevention and depression treatment trials, could provide great value for a very small investment. Many of the academic medical centers which were funded to recruit for this trial have EMR access. Also, NDI searches could be conducted on each member of the trials, if the proper permissions were obtained.

Data linkage approaches need to protect the privacy and security of individual information on suicidal behaviors and suicide-related risk factors. Because suicidal behaviors are relatively rare events, if a data system includes certain geographic identifiers such as county or school, it might be possible to identify a specific individual. Those carrying out linkage could use processes which ensure that individuals cannot be identified and that identifying data (e.g., name, date of birth, address) is not transferred between data sets. Data linkage procedures could be approved by an International Review Board and subject to data use policies and agreements. The legal feasibility of linkage depends on the applicability to the specific purpose of the data linkage of Federal and State legal protections for the confidentiality of health information and participation in human research, and also on any specific permissions obtained from individual patients for the use of their health information. Detailed guidelines on the technical and legal aspects of data linkage could be developed to facilitate work in this area. Data sharing agreements are needed.

There is a national discussion about integrating data from health care delivery systems and health insurance systems to create a national health research data infrastructure (e.g., PCORnet, FDA Sentinel, National Institutes of Health Precision Medicine Initiative (NIH PMI)). This type of national resource could advance linkage opportunities to suicide prevention data. Data linkage in suicide prevention needs to be a part of this national discussion.

### Suggested Next Steps

- Intervention harmonization: Approaches to advance intervention harmonization might allow for smaller studies of like interventions to be combined to increase statistical power. Biostatistical methods are needed for intervention harmonization across prevention studies aimed at youth suicide, as well as interventions directed at conditions in the causal pathway to suicide. This work could also advance the identification and study of mediators and moderators, which could allow for the targeting of specific interventions at high-risk groups. These new methodologic approaches are necessary because nearly all of the suicide prevention studies are underpowered to address mediation or moderation within their own studies.
- A National suicide outcomes data repository: Such a repository could be created to combine data from several sources to aim to establish better coverage of suicide ideation, suicide attempt, and suicide on a national level.
- Guidelines on data linkage methods and procedures: Such guidelines could be developed to facilitate the linkage of prevention data with external data systems.
- A Technical support center: A support center could be established to assist researchers, prevention scientists, health systems, States, and others with methods and procedures for data linkage.

## Conclusions

We identified only six studies that linked suicide prevention efforts with data systems, and none of these explored the effects of moderators. We identified 153 unique data systems, 66 of which we classified as “fairly accessible” with data dictionaries available. There is potential for linking existing data systems with existing suicide prevention efforts to assess the broader and extended impact of suicide prevention programs; however, limited availability of data dictionaries and lack of adherence to standard data elements limits the potential utility of linking prevention efforts with data systems.