# Appendix F Included Data Systems

Table F-1 Data systems with fairly accessible information and data dictionaries

Organization | Data System Name
AHRQ - Healthcare Cost and Utilization Project (HCUP) | Nationwide Inpatient Sample (NIS)
AHRQ - Healthcare Cost and Utilization Project (HCUP) | Kids' Inpatient Database (KID)
AHRQ - Healthcare Cost and Utilization Project (HCUP) | Nationwide Emergency Department Sample (NEDS)
AHRQ - Healthcare Cost and Utilization Project (HCUP) | State Inpatient Databases (SID)
AHRQ - Healthcare Cost and Utilization Project (HCUP) | State Ambulatory Surgery and Services Databases (SASD)
AHRQ - Healthcare Cost and Utilization Project (HCUP) | State Emergency Department Databases (SEDD)
American Association of Poison Control Centers (AAPCC) | National Poison Data System (NPDS)
American College of Surgeons | National Trauma Data Bank (NTDB)
Army | Army Study To Assess Risk and Resilience in Servicemembers (STARRS)
California Department of Public Health (CDPH) Portal: California EpiCenter | California Electronic Violent Death Reporting System (VDRS)
California Department of Public Health (CDPH) California Health and Human Services Open Data Portal (CHHS Open Data) California Department of Public Health Vital Statistics Advisory Committee (VSAC) California Health and Human Services Agency's Committee for the Protection of Human Subjects (CPHS) | California Death Data Files
CDC | National Survey of Prison Health Care (NSPHC)
CDC - National Center for Health Statistics (NCHS) | National Death Index (NDI)
CDC - National Center for Health Statistics (NCHS) | National Health and Nutrition Examination Survey (NHANES) (up to 2004)
CDC - National Center for Health Statistics (NCHS) | National Ambulatory Medical Care Survey (NAMCS)
CDC - National Center for Health Statistics (NCHS) | National Hospital Ambulatory Medical Care Survey (NHAMCS)
CDC - National Center for Health Statistics (NCHS) Portal: National Vital Statistics System (NVSS) | National Mortality Followback Survey (NMFS)
CDC - National Syndromic Surveillance Program (NSSP) | BioSense Data
CDC Portal: Web-based Injury Statistics Query and Reporting System (WISQARS) | National Violent Death Reporting System (NVDRS)
Census | National Longitudinal Mortality Study (NLMS)
Colorado Department of Public Health and Environment Portal: Colorado Health Information Dataset (CoHID) | Colorado Death Certificates and Data
Colorado Department of Public Health and Environment Portal: Colorado Health Information Dataset (CoHID) | Colorado Injury Hospital Data
Colorado Hospital Association (CHA) | Colorado Hospital Association Discharge Data
Connecticut Department of Health | Connecticut School Health Survey
Consumer Product Safety Commission | National Electronic Injury Surveillance System (NEISS)
DoD | DoD Survey of Health Related Behaviors
DoD Armed Forces - Armed Forces Health Surveillance Branch | Defense Medical Surveillance System (DMSS)
Federal Transit Administration | National Transit Database - Safety & Security Time Series Data
Florida Department of Health | Florida Death Rate Query System
Florida Health | Florida Injury Surveillance Data System
Healthy Minds Network | Research on Adolescent and Young Adult Mental Health
Illinois Department of Human Services (IDHS) | Illinois Youth Survey (IYS)
Illinois Department of Public Health (IDPH) | Illinois Trauma Registry Database
Illinois Department of Public Health (IDPH) - Emergency Medical Services | Illinois Prehospital Data Program
Illinois Department of Public Health (IDPH) Portal: EMS Data Reporting System | Illinois Hospital Discharge Database
Maine Health Data Organization (MHDO) | Maine All Payer Claims Database (APCD)
Maine Health Data Organization (MHDO) | Maine Hospital Inpatient and Outpatient Data
Maryland Department of Health and Mental Hygiene (DHMH) | Maryland Medicaid Claims
Maryland Department of Health and Mental Hygiene (M-DHMH) | Maryland Violent Death Reporting System (VDRS)
Michigan Department of Education | Michigan Youth Risk Behavior System (YRBS)
Minnesota Department of Health | Minnesota Injury Data Access System (MIDAS)
Missouri Department of Health &Senior Service | Missouri Death Records
Missouri Department of Health &Senior Service | Missouri Patient Abstract System (Hospital Discharges)
National Center for Health Statistics (NCHS) Portal: CDC WONDER (Wide-ranging Online Data for Epidemiologic Research) | Mortality Medical Data System (Multiple and Underlying Cause of Death Data Files)
National Center for the Review and Prevention of Child Deaths (NCRPCD) | National Child Death Review Case Reporting System
National Highway Traffic Safety Administration - EMS | National EMS Information System (NEMSIS)
National Institute of Mental Health (NIMH) | Collaborative Psychiatric Epidemiology Surveys (CPES)
New Mexico Department of Health | New Mexico Violent Death Reporting System (VDRS)
New York State Department of Health | New York State Statewide Planning and Research Cooperative System (SPARCS)
NIH - NIAAA (National Institute on Alcohol Abuse and Alcoholism) | National Epidemiologic Survey on Alcohol and Related Conditions (NESARC)
NIH and University of North Carolina | The National Longitudinal Study of Adolescent to Adult Health (Add Health)
Oregon Health Authority | Oregon Adolescent Suicide Attempt Data System (ASADS)
Oregon Health Authority | Oregon Healthy Teen Survey
Oregon Health Authority - Public Health Division | Oregon Student Wellness Survey
PennState Center for Collegiate Mental Health (CCMH) | CCMH Data Navigator
Pennsylvania Department of Education's Safe Schools Office | Pennsylvania Network for Student Assistance Services
Substance Abuse and Mental Health Service Administration (SAMHSA) | Emergency Department Data / Drug Abuse Warning Network (DAWN)
Substance Abuse and Mental Health Service Administration (SAMHSA) | Population Data / National Survey on Drug Use and Health (NSDUH)
Substance Abuse and Mental Health Service Administration (SAMHSA) - Mental Health Facilities Data | National Mental Health Services Survey (N-MHSS)
Suicide Prevention Data Center (SPDC) | The Garrett Lee Smith Memorial Suicide Prevention Program
Veteran Affairs | VA Behavioral Health Autopsy Program (BHAP)
Virginia Health Information | Virginia Hospital Discharges
Washington State Department of Health | Washington Healthy Youth Survey
Washington State Department of Health | Washington State Vital Statistics and Population Data (Death Data)
Washington State Department of Health | Washington State Comprehensive Hospital Abstract Reporting System (CHARS)
Wisconsin Hospital Association (WHA) - WHA Information Center | Wisconsin WIpop Data - Inpatient and Outpatient Discharge Summaries

CCMH=Center for Collegiate Mental Health;CDC=Centers for Disease Control and Prevention;CHA=Colorado Hospital Association;DoD=Department of Defense;EMS=Emergency Medical Services;NIH=National Institutes of Health;PA=Pennsylvania;UNC=University of North Carolina;WHA=Wisconsin Hospital Association;WIpop=Wisconsin population

Table F-2 Data systems with fairly accessible information but no accessible data dictionary

Organization | Data System Name
Alaska Department of Health and Social Services (ADHSS) - Statewide Suicide Prevention Council | Alaska Detailed Causes of Death
Arizona Department of Health Services; Office of Injury Prevention | Arizona Child Fatality Review Program
Bureau of Justice Statistics - Suicide and Homicide in State Prisons and Local Jails | [National] Deaths in Custody Reporting Program (DCRP)
California - Los Angeles County Public Health Department - Vital Records Office | Los Angeles County Mortality Dataset
California - Office of Statewide Health Planning and Development (OSHPD) | California Hospital Discharge Data
California Department of Corrections and Rehabilitation (CDCR) | California CDCR COMPSTAT
CDC | School-Associated Violent Death Study (SAVD)
CDC - National Center for Health Statistics (NCHS) | National Hospital Discharge Survey (NHDS)
CDC - National Center for Health Statistics (NCHS) | National Hospital Care Survey (NHCS)
Colorado Department of Public Health and Environment Portal: Colorado Health Information Dataset (CoHID) | Colorado Violent Death Report System (VDRS)
Connecticut Department of Public Health - State Vital Records Office | Connecticut Vital Records
Connecticut Department of Public Health - The Office of Injury Prevention | Connecticut Violent Death Reporting System (VDRS)
Connecticut Hospital Association & Connecticut Office of Health Care Access (OHCA) | Connecticut Chime Data
Delaware Child Death, Near Death and Stillbirth Commission (CDNDSC) | Delaware Child Death Review
Delaware Health and Social Services - Division of Public Health | Delaware Electronic Reporting and Syndromic Surveillance System (DERSS)
Delaware Health and Social Services - Division of Public Health - Delaware Health Statistics Center | Delaware Hospital Discharge Data
Georgia - Fulton County Medical Examiner | Georgia “Holds Our Medical Examiner Records” (HOMER)
Illinois Department of Public Health (IDPH) | Illinois Violent Death Reporting System (VDRS)
Illinois Department of Public Health (IDPH) - Center for Health Statistics | Illinois Vital Statistics
Illinois Department of Public Health (IDPH) - Center for Health Statistics Portal: iQuery | Illinois Project for Local Assessment of Needs (IPLAN)
Kentucky - Division of Medical Examiner's Services | Kentucky Medical Examiner Reports
Los Angeles County Public Health Department - The Injury & Violence Prevention Program (IVPP) | Los Angeles Injury Data and Reports
Maine Department of Health and Human Services - Maine Suicide Prevention Program | Maine Data, Research and Vital Statistics
Maryland Department of Health and Mental Hygiene (DHMH) | Maryland Vital Statistics and Reports (Death Certificates)
Massachusetts - Executive Office of Health and Human Services (EOHHS) | Massachusetts Violent Death Reporting System (VDRS)
National Center on Safe Supportive Learning Environments (NCSSLE) | School Climate Survey Compendia
Nebraska Department of Health and Human Services | Nebraska Child & Maternal Death Review Team
Nebraska Department of Health and Human Services | Nebraska Death Certificates
New Mexico Department of Health | New Mexico Youth Resiliency & Risk Survey (YRRS)
New Mexico Department of Health | New Mexico Vital Records
New York State Department of Health | New York State Vital Statistics
New York State Department of Health | New York State Suicide and Self-Inflicted Injuries
NIDA Substance Abuse and Mental Health Data Archive (SAMHDA) | Drug Abuse Treatment Outcome Survey (DATOS)
NIMH | Treatment for Adolescents with Depression Study (TADS)
NIMH and University of Pittsburgh | Treatment of SSRI-Resistant Depression In Adolescents (TORDIA)
Ohio Department of Health | Ohio Death Data and Statistics
Oklahoma Office of the Chief Medical Examiner | Oklahoma Medical Examiner Reports
Oklahoma State Department of Health (OSDH) | Oklahoma Violent Death Reporting System (VDRS)
Oregon Health Authority | Oregon Injury and Fatality Data
Oregon Health Authority | Oregon Death with Dignity Act Database
Oregon Health Authority | Oregon Death Data
Oregon Health Authority - Public Health Division | Oregon Violent Death Reporting System (VDRS)
Oregon State Police - Medical Examiner Division | Oregon Medical Examiner Reports
Texas Department of State Health Services - Center for Health Statistics | Texas Health Data (Death Data)
Truven Health Analytics | Truven MarketScan
UCLA Center for Health Policy Research | California Health Interview Survey (CHIS)
University of Pittsburgh - NIMH | Sequenced Treatment Alternatives to Relieve Depression
Utah Department of Health's Public Health Data Resource | Utah Public Health Indicator Based Information System (IBIS)
Virginia Department of Health | Virginia Violent Death Reporting System (VDRS)
Virginia Department of Health - Office of the Medical Examiner | Virginia Medical Examiner Reports
Washington State Department of Health | Washington State Injury Data Tables
Washington State Department of Health | Washington State Death with Dignity Data
Wisconsin Department of Health Services | Wisconsin Violent Death Reporting System (VDRS)
Wisconsin Department of Health Services | Wisconsin Death Database
Wyoming Department of Health | Wyoming Vital Records - Suicide Data

CDC=Centers for Disease Control and Prevention;CDCR= California Department of Corrections and Rehabilitation;COMPSTAT=Computer Statistics;LA=Los Angeles;NCHS=National Center for Health Statistics;NIDA=National Institute on Drug Abuse;NIMH=National Institute of Mental Health

Table F-3 Data systems with potentially accessible information

Organization | Data System Name
American College Health Association | National College Health Assessment (NCHA)
Association for University and College Counseling Center Directors (AUCCCD) | Directors Surveys
Bureau of Justice Statistics | Arrest-Related Deaths
Bureau of Justice Statistics | National Corrections Reporting Program (NCRP)
California Department of Public Health (CDPH) | California County Health Status Profiles
Delaware Health and Social Services - Delaware Health Statistics Center | Delaware STIPDA Injury Data
DoD | DoD Recruit Mortality Registry (RMR)
DoD | Department of Defense Suicide Event Report (DoDSER)
Los Angeles County Child & Adolescent Suicide Review Team | Los Angeles County Child & Adolescent Suicide Review
New Jersey Department of Health | New Jersey Violent Death Reporting System (VDRS)
North Carolina Department of Health and Human Services | North Carolina Surveillance and Vital Statistics Data
San Francisco Department of Public Health | San Francisco Violent Injury Reporting System
Suicide Prevention Action Network (SPAN) of Idaho | Idaho Youth Risk Behavior Survey (YRBS)
Tennessee | Tennessee Medicaid data
Texas Department of State Health Services - Center for Health Statistics | Texas Youth Risk Behavior Survey (YRBS)
Texas Department of State Health Services - Center for Health Statistics | Texas Injury Statistics
UChicago, Harvard, Columbia and NIJ | Project on Human Development in Chicago Neighborhoods (PHDCN)
Veteran Affairs | VA Suicide Surveillance and Clinical Support System
Virginia Department of Health | Virginia Syndromic Surveillance Data
WHO | WHO Mortality Database

CDC=Centers for Disease Control and Prevention;NIJ=National Institute of Justice;STIPDA= State and Territorial Injury Prevention Directors Association;DOD=Department of Defense;WHO=World Health Organization

Table F-4 Data systems with no information available on specifications

Organization | Data System Name
Annenberg Public Policy Center | National Annenberg Survey of Youth Datasets
Army | Army Behavioral Health Integrated Data Environment (ABHIDE)
CDC - Division of Adolescent and School Health (DASH) | Youth Risk Behavior Surveillance System (YRBSS)
Delaware Health and Social Services - Division of Public Health - Office of Vital Statistics | Delaware Birth and Death Records
Indian Health Services | IHS Behavioral Health Data Mart and Reporting System
Maryland Department of Health and Mental Hygiene (M-DHMH) | Maryland Assessment Tool for Community Health (MATCH)
National Center for Deaf Health Research (NCDHR) | Deaf Health Survey
National Emergency Number Association (NENA 911) | NENA [Database Name Unknown]
Tennessee | Tennessee Medicaid data
University of Pittsburgh | Pittsburgh Girls Study
VA - VISN 2 Center for Suicide Prevention | VA MIRECC/CoE
Washington State Department of Health | Washington State Trauma Registry (WTR)

CDC=Centers for Disease Control and Prevention;CoE= centers of excellence;HIS=Indian Helath Services;MIRECC=Mental Illness Research, Education and Clinical Centers;VA=Veterans Health Administration;VISN=Veterans Integrated Service Networks