# Appendix E Evidence Tables

Evidence Table E-1 Characteristics of studies identified in the literature search

## References for Appendix E

1 King CA, Hill RM, Wynne HA, et al. (2012). Adolescent suicide risk screening: the effect of communication about type of follow-up on adolescents' screening responses. J Clin Child Adolesc Psychol.
2 Diamond GS, Wintersteen MB, Brown GK, et al. (2010). Attachment-based family therapy for adolescents with suicidal ideation: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry.
3 Diamond G, Creed T, Gillham J, et al. (2012). Sexual trauma history does not moderate treatment outcome in Attachment-Based Family Therapy (ABFT) for adolescents with suicide ideation. J Fam Psychol.
4 Jobes DA, Lento R, Brazaitis K. (2012). An Evidence-Based Clinical Approach to Suicide Prevention in the Department of Defense: The Collaborative Assessment and Management of Suicidality (CAMS). Military Psychology (Taylor & Francis Ltd).
5 Eggert LL, Thompson EA, Randell BP, et al. (2002). Preliminary effects of brief school-based prevention approaches for reducing youth suicide--risk behaviors, depression, and drug involvement. J Child Adolesc Psychiatr Nurs.
6 Randell BP, Eggert LL, Pike KC. (2001). Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav.
7 Thompson EA, Eggert LL, Randell BP, et al. (2001). Evaluation of indicated suicide risk prevention approaches for potential high school dropouts. Am J Public Health.
8 Hooven C, Herting JR, Snedker KA. (2010). Long-term outcomes for the promoting CARE suicide prevention program. Am J Health Behav.
9 Oesterle S, Hawkins JD, Kuklinski MR, et al. (2015). Effects of Communities That Care on Males' and Females' Drug Use and Delinquency 9 Years After Baseline in a Community-Randomized Trial. Am J Community Psychol.
10 Godoy Garraza L, Walrath C, Goldston DB, et al. (2015). Effect of the Garrett Lee Smith Memorial Suicide Prevention Program on Suicide Attempts Among Youths. JAMA Psychiatry.
11 Walrath C, Garraza LG, Reid H, et al. (2015). Impact of the Garrett Lee Smith youth suicide prevention program on suicide mortality. Am J Public Health.
12 Wilcox HC, Kellam SG, Brown CH, et al. (2008). The impact of two universal randomized first- and second-grade classroom interventions on young adult suicide ideation and attempts. Drug Alcohol Depend.
13 Lynn CJ, Acri MC, Goldstein L, et al. (2014). Improving Youth Mental Health through Family-Based Prevention In Family Homeless Shelters. Child Youth Serv Rev.
14 Ilgen MA, Jain A, Lucas E, et al. (2007). Substance use-disorder treatment and a decline in attempted suicide during and after treatment. J Stud Alcohol Drugs.
15 Thompson EA, Eggert LL, Herting JR. (2000). Mediating effects of an indicated prevention program for reducing youth depression and suicide risk behaviors. Suicide Life Threat Behav.
16 Brown KJ, Block AJ. (2001). Evaluation of Project Chrysalis: A school-based intervention to reduce negative consequences of abuse. The Journal of Early Adolescence.
17 Hooven C, Walsh E, Pike KC, et al. (2012). Promoting CARE including parents in youth suicide prevention. Family & community health.
18 Asarnow JR, Berk M, Hughes JL, et al. (2015). The SAFETY Program: a treatment-development trial of a cognitive-behavioral family treatment for adolescent suicide attempters. J Clin Child Adolesc Psychol.
19 Hawkins JD, Kosterman R, Catalano RF, et al. (2005). Promoting positive adult functioning through social development intervention in childhood: long-term effects from the Seattle Social Development Project. Arch Pediatr Adolesc Med.
20 Aseltine RH, DeMartino R. (2004). An outcome evaluation of the SOS Suicide Prevention Program. Am J Public Health.
21 Aseltine RH, James A, Schilling EA, et al. (2007). Evaluating the SOS suicide prevention program: a replication and extension. BMC Public Health.
22 Biddle VS, Kern J, Brent DA, et al. (2014). Student Assistance Program Outcomes for Students at Risk for Suicide. Journal of School Nursing (Sage Publications Inc.).
23 King KA, Strunk CM, Sorter MT. (2011). Preliminary Effectiveness of Surviving the Teens<sup>®</sup> Suicide Prevention and Depression Awareness Program on Adolescents' Suicidality and Self-Efficacy in Performing Help-Seeking Behaviors. Journal of School Health.
24 Gutstein SE, Rudd MD. (1990). An outpatient treatment alternative for suicidal youth. J Adolesc.
25 March JS, Silva S, Petrycki S, et al. (2007). The Treatment for Adolescents With Depression Study (TADS): long-term effectiveness and safety outcomes. Arch Gen Psychiatry.
26 (2009). The Treatment for Adolescents with Depression Study (TADS): Outcomes over 1 year of naturalistic follow-up. Am J Psychiatry.
27 Vitiello B, Silva SG, Rohde P, et al. (2009). Suicidal events in the Treatment for Adolescents with Depression Study (TADS). Journal of Clinical Psychiatry.
28 Curry J, Silva S, Rohde P, et al. (2011). Recovery and recurrence following treatment for adolescent major depression. Arch Gen Psychiatry.
29 Brent DA, Greenhill LL, Compton S, et al. (2009). The Treatment of Adolescent Suicide Attempters study (TASA): predictors of suicidal events in an open treatment trial. J Am Acad Child Adolesc Psychiatry.
30 Vitiello B, Brent DA, Greenhill LL, et al. (2009). Depressive symptoms and clinical status during the Treatment of Adolescent Suicide Attempters (TASA) Study. J Am Acad Child Adolesc Psychiatry.
31 Wolk CB, Kendall PC, Beidas RS. (2015). Cognitive-behavioral therapy for child anxiety confers long-term protection from suicidality. Journal of the American Academy of Child & Adolescent Psychiatry.
32 Asarnow JR, Porta G, Spirito A, et al. (2011). Suicide attempts and nonsuicidal self-injury in the treatment of resistant depression in adolescents: findings from the TORDIA study. J Am Acad Child Adolesc Psychiatry.
33 Emslie GJ, Mayes T, Porta G, et al. (2010). Treatment of resistant depression in adolescents (TORDIA): Week 24 outcomes. Am J Psychiatry.
34 Shamseddeen W, Clarke G, Wagner KD, et al. (2011). Treatment-resistant depressed youth show a higher response rate if treatment ends during summer school break. Journal of the American Academy of Child & Adolescent Psychiatry.
35 Woldu H, Porta G, Goldstein T, et al. (2011). Pharmacokinetically and clinician-determined adherence to an antidepressant regimen and clinical outcome in the TORDIA trial. J Am Acad Child Adolesc Psychiatry.
36 Knox KL, Litts DA, Talcott GW, et al. (2003). Risk of suicide and related adverse outcomes after exposure to a suicide prevention programme in the US Air Force: cohort study. BMJ.
37 King CA, Kramer A, Preuss L, et al. (2006). Youth-Nominated Support Team for Suicidal Adolescents (Version 1): a randomized controlled trial. J Consult Clin Psychol.
38 King CA, Klaus N, Kramer A, et al. (2009). The Youth-Nominated Support Team-Version II for suicidal adolescents: A randomized controlled intervention trial. J Consult Clin Psychol.
39 Anestis MD, Anestis JC. (2015). Suicide Rates and State Laws Regulating Access and Exposure to Handguns. Am J Public Health.
40 Asarnow JR, Baraff LJ, Berk M, et al. (2011). An emergency department intervention for linking pediatric suicidal patients to follow-up mental health treatment. Psychiatr Serv.
41 Brown GK, Ten Have T, Henriques GR, et al. (2005). Cognitive therapy for the prevention of suicide attempts: a randomized controlled trial. JAMA.
42 Collins JC, McFarland BH. (2008). Divalproex, lithium and suicide among Medicaid patients with bipolar disorder. J Affect Disord.
43 Cooper SL, Lezotte D, Jacobellis J, et al. (2006). Does Availability of Mental Health Resources Prevent Recurrent Suicidal Behavior? An Ecological Analysis. Suicide and Life-Threatening Behavior.
44 Farmer KA, Felthous AR, Holzer CE. (1996). Medically serious suicide attempts in a jail with a suicide-prevention program. J Forensic Sci.
45 Fleegler EW, Lee LK, Monuteaux MC, et al. (2013). Firearm legislation and firearm-related fatalities in the United States. JAMA Intern Med.
46 Gardner W, Klima J, Chisolm D, et al. (2010). Screening, triage, and referral of patients who report suicidal thought during a primary care visit. Pediatrics.
47 Huey SJ, Henggeler SW, Rowland MD, et al. (2004). Multisystemic therapy effects on attempted suicide by youths presenting psychiatric emergencies. J Am Acad Child Adolesc Psychiatry.
48 Kaminer Y, Burleson JA, Goldston DB, et al. (2006). Suicidal ideation among adolescents with alcohol use disorders during treatment and aftercare. Am J Addict.
49 Kennard BD, Emslie GJ, Mayes TL, et al. (2014). Sequential treatment with fluoxetine and relapse--prevention CBT to improve outcomes in pediatric depression. Am J Psychiatry.
50 Kerr DC, DeGarmo DS, Leve LD, et al. (2014). Juvenile justice girls' depressive symptoms and suicidal ideation 9 years after Multidimensional Treatment Foster Care. J Consult Clin Psychol.
51 Olfson M, Shaffer D, Marcus SC, et al. (2003). Relationship between antidepressant medication treatment and suicide in adolescents. Arch Gen Psychiatry.
52 Rathus JH, Miller AL. (2002). Dialectical behavior therapy adapted for suicidal adolescents. Suicide Life Threat Behav.
53 Rotheram-Borus MJ, Piacentini J, Cantwell C, et al. (2000). The 18-month impact of an emergency room intervention for adolescent female suicide attempters. J Consult Clin Psychol.
54 Rudd MD, et al. (1996). Effectiveness of an Outpatient Intervention Targeting Suicidal Young Adults: Preliminary Results. J Consult Clin Psychol.
55 Segal HG, King CA, Naylor MW. (1995). Psychosocial functioning of severely disturbed adolescents after short-term hospitalization. Psychiatr Serv.
56 Spirito A, Plummer B, Gispert M, et al. (1992). Adolescent suicide attempts: outcomes at follow-up. Am J Orthopsychiatry.
57 Warner CH, Appenzeller GN, Parker JR, et al. (2011). Effectiveness of mental health screening and coordination of in-theater care prior to deployment to iraq: a cohort study. American Journal of Psychiatry.
58 Wharff EA, Ginnis KM, Ross AM. (2012). Family-based crisis intervention with suicidal adolescents in the emergency room: a pilot study. Soc Work.
59 Wingate LR, Van Orden KA, Joiner TE, et al. (2005). Comparison of compensation and capitalization models when treating suicidality in young adults. J Consult Clin Psychol.