# Appendix D Results of the Literature Search

Figure D-1 Results of the literature search

* CINAHL, PsycINFO, and ERIC were searched simultaneously through the EBSCO database

† Campbell Collaboration Library of Systematic Reviews

‡ Sum of excluded articles exceeds 3723 because reviewers were not required to agree on reasons for exclusion

§ Sum of the excluded articles exceeds 412 because reviewers were not required to agree on the reason for exclusion

Describes the flow of articles identified in the systematic literature search including 4198 unique citations and resulting in 47 included studies described in 59 articles.