# Appendix C Environmental Scan Coding Scheme

Table C-1 Environmental scan coding schema

ID# | Topics | Level | Type | Must Code
1 | Data System Specification and Meta Information | 1 | | x
1 | Review method and information source used to find it | 2 | | x
1 | Systematic review | 3 | Y/N/? | x
1 | IN | 4 | Y/N/? | x
1 | OUT | 4 | Y/N/? | x
1 | Environmental scan | 3 | Y/N/? | x
1 | Google | 4 | Y/N/? | x
1 | Yahoo | 4 | Y/N/? | x
1 | Bing | 4 | Y/N/? | x
1 | Appendix A: NREPP Database of Suicide Prevention Programs | 4 | Y/N/? | x
1 | Appendix D: Potential Data Systems | 4 | Y/N/? | x
1 | NAASP paper | 4 | Y/N/? | x
1 | AFSP/AAS/SPRC | 4 | Y/N/? | x
1 | Ad-hoc search | 4 | Y/N/? | x
1 | Targeted search | 3 | Y/N/? | x
1 | CA | 4 | Y/N/? | x
1 | OR | 4 | Y/N/? | x
1 | MD | 4 | Y/N/? | x
1 | DE | 4 | Y/N/? | x
1 | IL | 4 | Y/N/? | x
1 | WI | 4 | Y/N/? | x
1 | City | 4 | Y/N/? | x
1 | City name | 4 | text-name | x
1 | Community | 4 | Y/N/? | x
1 | Community name | 4 | text-name | x
1 | Name of the database / data system (if any) | 2 | text-name | x
1 | Data custodian | 2 | | x
1 | Name | 3 | text-name | x
1 | Contact email address | 3 | email | optional
1 | Contact phone number | 3 | phone | optional
1 | Web Link/URL | 2 | | x
1 | URL - generic / home page of the study or data custodian | 3 | URL | x
1 | URL - data dictionary and/or public use file | 3 | URL | x
1 | URL - additional useful links (e.g., reports) #1 | 3 | URL | x
1 | URL - additional useful links (e.g., reports) #2 | 3 | URL | optional
1 | URL - additional useful links (e.g., reports) #3 | 3 | URL | optional
1 | URL - additional useful links (e.g., reports) #4 | 3 | URL | optional
1 | URL - additional useful links (e.g., reports) #5 | 3 | URL | optional
1 | Level of information avaiable for this data system | 2 | | x
1 | Data exists and can be acquired (free or for a fee) | 3 | Y/N/? | x
1 | Data is publicly available and can be downloaded (e.g., PUF) | 4 | Y/N/? | x
1 | Data can be acquired but requires an automated registration | 4 | Y/N/? | x
1 | Data can be acquired if confirmed by a person (e.g., needs email comm) | 4 | Y/N/? | x
1 | Data dictionary or code book is accessible | 3 | Y/N/? | x
1 | Formal data dictionary (e.g., xml, xls, pdf) | 4 | Y/N/? | optional
1 | Informal data dictionary (e.g., data intake survey) | 4 | Y/N/? | optional
1 | Proxy data dictionaries (e.g., reports) which may not have all variables | 4 | Y/N/? | optional
1 | Web page for this data system includes | 3 | Y/N/? | optional
1 | summary of what the data system is about | 4 | Y/N/? | optional
1 | some detailed information about the data system | 4 | Y/N/? | optional
1 | high level of details about the data system | 4 | Y/N/? | optional
1 | Data Use / Functions | 2 | | x
1 | Primary function of the data system / database | 3 | | x
1 | Reseach (e.g., academic, pharma) | 4 | Y/N/? | x
1 | Clinical care / operations | 4 | Y/N/? | x
1 | Administrative services (e.g., census) | 4 | Y/N/? | x
1 | Public health (e.g., surveillance) | 4 | Y/N/? | x
1 | Other | 4 | text | x
1 | Secondary function of the data system | 3 | text | optional
2 | Geographic Coverage | 1 | | x
2 | Countries | 2 | | x
2 | US | 3 | Y/N/? | x
2 | Other (non-US) | 3 | text-list | x
2 | US coverage | 2 | | x
2 | US - national | 3 | Y/N/? | x
2 | US - regional (e.g., east coast) | 3 | Y/N/? | x
2 | US - state level (e.g., Maryland) | 3 | Y/N/? | x
2 | US - smaller than state level | 3 | Y/N/? | x
2 | County | 4 | Y/N/? | x
2 | Zip code | 4 | Y/N/? | x
2 | Census block | 4 | Y/N/? | x
2 | Tribal | 4 | Y/N/? | x
2 | Teritory | 4 | Y/N/? | x
2 | Islands | 4 | Y/N/? | x
2 | Other | 4 | text | x
2 | US states | 2 | | x
2 | Alabama (AL) | 3 | Y/N/? | x
2 | Alaska (AK) | 3 | Y/N/? | x
2 | Arizona (AZ) | 3 | Y/N/? | x
2 | Arkansas (AR) | 3 | Y/N/? | x
2 | California (CA) | 3 | Y/N/? | x
2 | Colorado (CO) | 3 | Y/N/? | x
2 | Connecticut (CT) | 3 | Y/N/? | x
2 | Delaware (DE) | 3 | Y/N/? | x
2 | Florida (FL) | 3 | Y/N/? | x
2 | Georgia (GA) | 3 | Y/N/? | x
2 | Hawaii (HI) | 3 | Y/N/? | x
2 | Idaho (ID) | 3 | Y/N/? | x
2 | Illinois (IL) | 3 | Y/N/? | x
2 | Indiana (IN) | 3 | Y/N/? | x
2 | Iowa (IA) | 3 | Y/N/? | x
2 | Kansas (KS) | 3 | Y/N/? | x
2 | Kentucky (KY) | 3 | Y/N/? | x
2 | Louisiana (LA) | 3 | Y/N/? | x
2 | Maine (ME) | 3 | Y/N/? | x
2 | Maryland (MD) | 3 | Y/N/? | x
2 | Massachusetts (MA) | 3 | Y/N/? | x
2 | Michigan (MI) | 3 | Y/N/? | x
2 | Minnesota (MN) | 3 | Y/N/? | x
2 | Mississippi (MS) | 3 | Y/N/? | x
2 | Missouri (MO) | 3 | Y/N/? | x
2 | Montana (MT) | 3 | Y/N/? | x
2 | Nebraska (NE) | 3 | Y/N/? | x
2 | New Hampshire (NH) | 3 | Y/N/? | x
2 | New Jersey (NJ) | 3 | Y/N/? | x
2 | New Mexico (NM) | 3 | Y/N/? | x
2 | New York (NY) | 3 | Y/N/? | x
2 | North Carolina (NC) | 3 | Y/N/? | x
2 | North Dakota (ND) | 3 | Y/N/? | x
2 | Ohio (OH) | 3 | Y/N/? | x
2 | Oklahoma (OK) | 3 | Y/N/? | x
2 | Oregon (OR) | 3 | Y/N/? | x
2 | Pennsylvania (PA) | 3 | Y/N/? | x
2 | Rhode Island (RI) | 3 | Y/N/? | x
2 | South Carolina (SC) | 3 | Y/N/? | x
2 | South Dakota (SD) | 3 | Y/N/? | x
2 | Tennessee (TN) | 3 | Y/N/? | x
2 | Texas (TX) | 3 | Y/N/? | x
2 | Utah (UT) | 3 | Y/N/? | x
2 | Vermont (VT) | 3 | Y/N/? | x
2 | Virginia (VA) | 3 | Y/N/? | x
2 | Washington (WA) | 3 | Y/N/? | x
2 | West Virginia (WV) | 3 | Y/N/? | x
2 | Wisconsin (WI) | 3 | Y/N/? | x
2 | Wyoming (WY) | 3 | Y/N/? | x
2 | Other (e.g., islands, teritories…) | 3 | text-list | x
3 | Demographic Coverage | 1 | | x
3 | Target population | 2 | | x
3 | American Indian (Tribal) | 3 | Y/N/? | x
3 | LGBT | 3 | Y/N/? | x
3 | Military | 3 | Y/N/? | x
3 | Prison | 3 | Y/N/? | x
3 | Students (schools/campuses) | 3 | Y/N/? | x
3 | General population | 3 | Y/N/? | x
3 | Other | 3 | text | x
4 | Data Granularity | 1 | | x
4 | Patient-level data exists (patient-level linkage possible) | 2 | Y/N/? | x
4 | Aggregated on certain dimensions (ecological linkage possible) | 2 | Y/N/? | x
4 | Demographics | 3 | Y/N/? | x
4 | Geographic | 3 | Y/N/? | x
4 | Clinical specifications | 3 | Y/N/? | x
4 | Entity | 3 | Y/N/? | x
4 | Data Sampling | 2 | Y/N/? | x
5 | Variables (if data dictionary is available) | 1 | | x
5 | Dependent variables | 2 | | x
5 | Primary | 3 | Y/N/? | x
5 | Suicide completion | 4 | Y/N/? | x
5 | Suicide attempt | 4 | Y/N/? | x
5 | Suicide ideation | 4 | Y/N/? | x
5 | Secondary / Intermediate | 3 | Y/N/? | optional
5 | Psychiatric and substance abuse disorders | 4 | Y/N/? | optional
5 | Service use for psychiatric and substance abuse disorders (e.g. ER visit) | 4 | Y/N/? | optional
5 | Graduation rates (e.g., educational, training) | 4 | Y/N/? | optional
5 | Incarceration rates | 4 | Y/N/? | optional
5 | Violence (both perpetrator and victim) | 4 | Y/N/? | optional
5 | Social support and connectedness | 4 | Y/N/? | optional
5 | Access to lethal means | 4 | Y/N/? | optional
5 | Other | 4 | text-list | optional
6 | Data Scalability | 1 | | x
6 | Data types | 2 | | x
6 | Suicide specific | 3 | Y/N/? | x
6 | Death records | 3 | Y/N/? | x
6 | Healthcare provider records (e.g., EHRs) | 3 | Y/N/? | x
6 | Population-based surveys | 3 | Y/N/? | x
6 | Health insurance claims | 3 | Y/N/? | x
6 | Other | 3 | text | x
6 | Updates and Data Collection | 2 | | x
6 | Ongoing | 3 | Y/N/? | x
6 | Stopped | 3 | Y/N/? | x
6 | Year Data Collection Started | 3 | date (YYYY) | x
6 | Year Data Collection Stopped | 3 | date (YYYY) | x
7 | Data Governance | 1 | | x
7 | Data access | 2 | | x
7 | Unrestricted | 3 | Y/N/? | x
7 | PUF (public use file) URL | 4 | URL | optional
7 | requires registration | 4 | Y/N/? | optional
7 | Restricted | 3 | Y/N/? | x
7 | can be used for research | 4 | Y/N/? | x
7 | can be used for clinical care / operations | 4 | Y/N/? | x
7 | can be used for commercial purposes | 4 | Y/N/? | x
7 | Data commodity | 2 | | x
7 | free | 3 | Y/N/? | x
7 | commercial / has a fee | 3 | Y/N/? | x
7 | type of license | 3 | text | x
8 | Excldue PICOTS Reason | 1 | Y/N/? | x
8 | Population(s) | 2 | Y/N/? | x
8 | Explain | 3 | text | x
8 | Intervention(s) | 2 | Y/N/? | x
8 | Explain | 3 | text | x
8 | Comparison(s) | 2 | Y/N/? | x
8 | Explain | 3 | text | x
8 | Outcome(s) | 2 | Y/N/? | x
8 | Explain | 3 | text | x
8 | Timing | 2 | Y/N/? | x
8 | Explain | 3 | text | x
8 | Setting | 2 | Y/N/? | x
8 | Explain | 3 | text | x
8 | Other? | 2 | text | x