# Appendix B Search Strategies

Table B-1 PubMed search strategy

# | Search
1 | suicide/prevention[mh]
2 | Suicide, Attempted/prevention[mh]
3 | suicid*[tiab] AND (prevent[tiab] OR prevention[tiab])
4 | 1 OR 2 OR 3
5 | clinical trial[pt]
6 | “Non-randomized”[tiab]
7 | Nonrandomized[tiab]
8 | cohort[tiab]
9 | “next study”[tiab]
10 | observational[tiab]
11 | “Case-control”[tiab]
12 | “cohort studies”[mh]
13 | cross-over studies[mh]
14 | prospectiv*[tiab]
15 | registr*[tiab]
16 | restrospectiv*[tiab]
17 | “Comparative Study” [pt]
18 | “propensity score”[tiab]
19 | “propensity Score”[mh]
20 | 5 OR 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12 OR 13 OR 14 OR 15 OR 16 OR 17 OR 18 OR 19
21 | 4 AND 20
22 | 1990:2016[dp]
23 | Eng[la]
24 | 4 AND 20 AND 22 AND 23

Table B-2 Cochrane Library search strategy

#1 | MeSH descriptor: [Suicide] explode all trees and with qualifier(s): [Prevention & control - PC]
#2 | suicid*:ti,ab,kw (Word variations have been searched)
#3 | prevent:ti,ab,kw (Word variations have been searched)
#4 | “prevention”:ti,ab,kw (Word variations have been searched)
#5 | #1 or (#2 and (#3 or #4)
Publication Year from 1990 to 2015

Table B-3 CINAHL, PsycINFO and ERIC search strategy

S26 | S7 AND S23 | Limiters - Published Date: 19900101-20151231 Narrow by Language: - English Search modes - Boolean/Phrase
S25 | S7 AND S23 | Narrow by Language: - English Search modes - Boolean/Phrase
S24 | S7 AND S23 | Search modes - Boolean/Phrase
S23 | S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 | Search modes - Boolean/Phrase
S22 | TX propensity score | Search modes - Boolean/Phrase
S21 | TX comparative study | Search modes - Boolean/Phrase
S20 | TX comparative study | Search modes - Boolean/Phrase
S19 | TX retrospective study | Search modes - Boolean/Phrase
S18 | TX registry | Search modes - Boolean/Phrase
S17 | TX prospectiv* | Search modes - Boolean/Phrase
S16 | TX “cross over” | Search modes - Boolean/Phrase
S15 | TX case control study | Search modes - Boolean/Phrase
S14 | TX observational study | Search modes - Boolean/Phrase
S13 | TX cohort study | Search modes - Boolean/Phrase
S12 | TX “follow up” OR TX “follow-up” OR TX Followup | Search modes - Boolean/Phrase
S11 | TX “next study” | Search modes - Boolean/Phrase
S10 | TX “non-randomized” | Search modes - Boolean/Phrase
S9 | TX nonrandomized | Search modes - Boolean/Phrase
S8 | TX “clinical Trials” | Search modes - Boolean/Phrase
S7 | S5 AND S6 | Search modes - Boolean/Phrase
S6 | S3 OR S4 | Search modes - Boolean/Phrase
S5 | S1 OR S2 | Search modes - Boolean/Phrase
S4 | TX Prevention | Search modes - Boolean/Phrase
S3 | TX Prevent | Search modes - Boolean/Phrase
S2 | TX suicid* | Search modes - Boolean/Phrase
S1 | SU Suicide | Search modes - Boolean/Phrase

Table B-4 The Campbell Collaboration Library of Systematic Reviews

suicide AND prevention