# Appendix A Acronyms

Acronym: Definition
AAS: American Association of Suicidology
AFSP: American Foundation for Suicide Prevention
AHRQ: Agency for Healthcare Research and Quality
ANOVA: Analysis of variance
APCD: All Payer Claims Databases
BRFSS: Behavioral Risk Factors Surveillance System
CAMS: The Collaborative Assessment and Management of Suicidality
CARE: Care, Assess, Respond, Empower
CAST: Coping and Support Training
CATCH-IT: Competent Adulthood Transition With Cognitive Behavioral And Interpersonal Training
C-CARE: Counselors: Care, Assess, Respond, Empower
CDC: Centers for Disease Control and Prevention
CINAHL: Cumulative Index to Nursing and Allied Health Literature
DSTF: Data and Surveillance Task Force
EMR: healthcare provider records (electronic medical records)
EPC: Evidence-base Practice Center
ER: Emergency room
ED: Emergency department
ERIC: Education Resources Information Center
FDA: Food and Drug Administration
GLS: The Garrett Lee Smith Memorial Suicide Prevention Program
HIE: Health Information Exchanges
HIPAA: Health Insurance Portability and Accountability Act
KQ: Key Question
LAUNCH: Linking Actions for Unmet Needs in Children's Health
LGBTQ: Lesbian, gay, bi-sexual, transgender, queer
MeSH: Medical Subject Heading
NAASP: National Action Alliance for Suicide Prevention
NASY+: National Annenberg Survey of Youth
NIH: National Institutes of Health
NR: not reported
NREPP: National Registry of Evidence-based Programs and Practices
NVDRS: National Violent Death Reporting
PGC: Personal Growth Class
PHI: Protected Health Information
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, Setting
PUF: Participant user files
RCT: Randomized controlled trial
SAMHSA: Substance Abuse and Mental Health Services Administration
SOFTADS: Survey of Outcomes Following Treatment for Adolescent Depression
SOS: Signs Of Suicide
SPRC: Suicide Prevention Resource Center
SRDR: Systematic Review Data Repository™
TADS: Treatment for Adolescents with Depression Study
TASA: Treatment of Adolescent Suicide Attempters
TORDIA: Treatment of Resistant Depression in Adolescents
YST-1: Youth-Nominated Support Team for Suicidal Adolescents (Version 1)
YST-2: Youth-Nominated Support Team for Suicidal Adolescents (Version 2)
WISQARS: Web-based Injury Statistics Query and Reporting