# References

1 Renders CM, Valk GD, Griffin SJ, et al. (2000). Interventions to improve the management of diabetes mellitus in primary care, outpatient and community settings. Cochrane Database Syst Rev.
2 Landon BE, Hicks LS, O'malley AJ, et al. (2007). Improving the management of chronic disease at community health centers. N Engl J Med.
3 Couch R, Jetha M, Dryden DM, et al. (2008). Diabetes education for children with type 1 diabetes mellitus and their families.
4 Hampson SE, Skinner TC, Hart J, et al. (2000). Behavioral interventions for adolescents with type 1 diabetes: how effective are they?. Diabetes Care.
5 Hood KK, Rohan JM, Peterson CM, et al. (2010). Interventions with adherence-promoting components in pediatric type 1 diabetes: meta-analysis of their impact on glycemic control. Diabetes Care.
6 Murphy HR, Rayman G, Skinner TC. (2006). Psycho-educational interventions for children and young people with type 1 diabetes. Diabet Med.
7 Urban AD, Berry D, Grey M. (2004). Optimizing outcomes in adolescents with type 1 diabetes and their families. J Clinic Outcomes Manag.
8 American Diabetes Association. (2014). Diagnosis and classification of diabetes mellitus. Diabetes Care.
9 Centers for Disease Control and Prevention. (2014). National Diabetes Statistics Report, 2014.
10 Pettitt DJ, Talton J, Dabelea D, et al. (2014). Prevalence of diabetes in U.S. youth in 2009: the search for diabetes in youth study. Diabetes Care.
11 Search for Diabetes in Youth Study Group. (2006). The burden of diabetes mellitus among us youth: prevalence estimates from the search for diabetes in youth study. Pediatrics.
12 Agency for Healthcare Research and Quality. (2012). 2012 National Healthcare Disparities Report: Chapter 2. Effectiveness (continued).
13 Gallegos-Macias AR, Macias SR, Kaufman E, et al. (2003). Relationship between glycemic control, ethnicity and socioeconomic status in hispanic and white non-Hispanic youths with type 1 diabetes mellitus. Pediatr Diabetes.
14 Schillinger D, Grumbach K, Piette J, et al. (2002). Association of health literacy with diabetes outcomes. JAMA.
15 Valenzuela JM, Seid M, Waitzfelder B, et al. (2014). Prevalence of and disparities in barriers to care experienced by youth with type 1 diabetes. J Pediatr.
16 Dall TM, Zhang Y, Chen YJ, et al. (2010). The economic burden of diabetes. Health affairs (Project Hope).
17 Centers for Disease Control and Prevention. (2012). Diabetes Report Card 2012.
18 Bystritsky A, Danial J, Kronemyer D. (2014). Interaction between diabetes and anxiety and depression: implications for treatment. Endocrinol Metab Clin N Am.
19 American Diabetes Association. (2014). Standards of medical care in diabetes-2014. Diabetes Care.
20 Diabetes Control and Complications Trial Research Group. (1993). The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. N Engl J Med.
21 Nathan DM. (2014). The diabetes control and complications trial/epidemiology of diabetes interventions and complications study at 30 years: overview. Diabetes Care.
22 Orchard TJ, Nathan DM, Zinman B, et al. (2015). Association between 7 years of intensive treatment of type 1 diabetes and long-term mortality. JAMA.
23 Fullerton B, Jeitler K, Seitz M, et al. (2014). Intensive glucose control versus conventional glucose control for type 1 diabetes mellitus. Cochrane Database Syst Rev.
24 UK Prospective Diabetes Study (UKPDS) Group. (1998). Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). Lancet.
25 UK Prospective Diabetes Study (UKPDS) Group. (1998). Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). Lancet.
26 Hemmingsen B, Lund SS, Gluud C, et al. (2013). Targeting intensive glycaemic control versus targeting conventional glycaemic control for type 2 diabetes mellitus. Cochrane Database Syst Rev.
27 Colhoun HM, Betteridge DJ, Durrington PN, et al. (2004). Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the collaborative atorvastatin diabetes study (CARDS): multicentre randomised placebo-controlled trial. Lancet.
28 Heart Protection Study Collaborative Group. (2003). MRC/BHF heart protection study of cholesterol-lowering with simvastatin in 5963 people with diabetes: a randomised placebo-controlled trial. Lancet.
29 UK Prospective Diabetes Study Group. (1998). Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes (UKPDS 38). BMJ.
30 Lv J, Neal B, Ehteshami P, et al. (2012). Effects of intensive blood pressure lowering on cardiovascular and renal outcomes: a systematic review and meta-analysis. PLoS Med.
31 Griffin S. (1998). Diabetes care in general practice: meta-analysis of randomised control trials. BMJ.
32 Tomky D, Cypress M, Dang D, et al. (2008). AADE7 self-care behaviors. Diabetes Educ.
33 Norris SL, Zhang X, Avenell A, et al. (2004). Long-term effectiveness of lifestyle and behavioral weight loss interventions in adults with type 2 diabetes: a meta-analysis. Am J Med.
34 Schellenberg ES, Dryden DM, Vandermeer B, et al. (2013). Lifestyle interventions for patients with and at risk for type 2 diabetes: a systematic review and meta-analysis. Ann Intern Med.
35 Thomas DE, Elliott EJ, Naughton GA. (2006). Exercise for type 2 diabetes mellitus. Cochrane Database Syst Rev.
36 Watts NB, Spanheimer RG, Digirolamo M, et al. (1990). Prediction of glucose response to weight loss in patients with non-insulin-dependent diabetes mellitus. Arch Intern Med.
37 Funnell M. (2013). Beyond the data: Moving towards a new DAWN in diabetes. Diabet Med.
38 Peyrot M, Rubin RR, Lauritzen T, et al. (2005). Psychosocial problems and barriers to improved diabetes management: results of the cross-national diabetes attitudes, wishes and needs (DAWN) study. Diabet Med.
39 International Diabetes Federation. (2011). Position statement: self-management education. Brussels, Belgium: International Diabetes Federation.
40 Knight KM, Dornan T, Bundy C. (2006). The diabetes educator: trying hard, but must concentrate more on behaviour. Diabet Med.
41 Norris SL, Engelgau MM, Narayan KM. (2001). Effectiveness of self-management training in type 2 diabetes: a systematic review of randomized controlled trials. Diabetes Care.
42 Haas L, Maryniuk M, Beck J, et al. (2013). National standards for diabetes self-management education and support. Diabetes Care.
43 Jones H, Berard LD, Macneill G, et al. (2013). Clinical practice guidelines: self-management education. Can J Diabetes.
44 National Institute for Health and Clinical Excellence. (2010). The management of type 2 diabetes. National Institute for Health and Clincial Excellence, editor.
45 Hoerger TJ, Segel JE, Gregg EW, et al. (2008). Is glycemic control improving in U.S. adults?. Diabetes Care.
46 Chodosh J, Morton SC, Mojica W, et al. (2005). Meta-analysis: chronic disease self-management programs for older adults. Ann Intern Med.
47 Deakin T, Mcshane CE, Cade JE, et al. (2005). Group based training for self-management strategies in people with type 2 diabetes mellitus. Cochrane Database Syst Rev.
48 Fan L, Sidani S. (2009). Effectiveness of diabetes self-management education intervention elements: a meta-analysis. Can J Dibetes.
49 Gary TL, Genkinger JM, Guallar E, et al. (2003). Meta-analysis of randomized educational and behavioral interventions in type 2 diabetes. Diabetes Educ.
50 Minet L, Moller S, Vach W, et al. (2010). Mediating the effect of self-care management intervention in type 2 diabetes: a meta-analysis of 47 randomised controlled trials. Patient Educ Couns.
51 Norris SL, Lau J, Smith SJ, et al. (2002). Self-management education for adults with type 2 diabetes: a meta-analysis of the effect on glycemic control. Diabetes Care.
52 Warsi A, Wang PS, Lavalley MP, et al. (2004). Self-management education programs in chronic disease: a systematic review and methodological critique of the literature. Arch Intern Med.
53 Medical Advisory Secretariat. (2009). Behavioural interventions for type 2 diabetes: an evidence-based analysis. Ont Health Technol Assess Ser.
54 Ellis SE, Speroff T, Dittus RS, et al. (2004). Diabetes patient education: a meta-analysis and meta-regression. Patient Educ Couns.
55 Glazier RH, Bajcar J, Kennie NR, et al. (2006). A systematic review of interventions to improve diabetes care in socially disadvantaged populations. Diabetes Care.
56 Michie S, Ashford S, Sniehotta FF, et al. (2011). A refined taxonomy of behaviour change techniques to help people change their physical activity and healthy eating behaviours: the CALO-RE taxonomy. Psychol Health.
57 Public Health Agency of Canada. (2010). Glossary of terms.
58 Piette JD. (2007). Interactive behavior change technology to support diabetes self-management: where do we stand?. Diabetes Care.
59 Agency for Healthcare Research and Quality. (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
60 University of Alberta Evidence-Based Practice Center. (2014). Behavioral programs for diabetes mellitus (protocol).
61 Higgins JP, Green S. (2011). Section 6.4.11.1. Search filters.
62 Malik K, Human Development Report 2013 Team. (2013). Human Development Report 2013. The rise of the south: human progress in a diverse world.
63 Ohkubo Y, Kishikawa H, Araki E, et al. (1995). Intensive insulin therapy prevents the progression of diabetic microvascular complications in Japanese patients with non-insulin-dependent diabetes mellitus: a randomized prospective 6-year study. Diabetes Res Clin Pract.
64 Hartling L, Bond K, Santaguida PL, et al. (2011). Testing a tool for the classification of study designs in systematic reviews of interventions and exposures showed moderate reliability and low accuracy. J Clin Epidemiol.
65 Higgins JPT, Green S. (2009). Cochrane Handbook for Systematic Reviews of Interventions.
66 Pimouguet C, Le Goff M, Thiebaut R, et al. (2011). Effectiveness of disease-management programs for improving diabetes care: a meta-analysis. CMAJ.
67 Tricco AC, Ivers NM, Grimshaw JM, et al. (2012). Effectiveness of quality improvement strategies on the management of diabetes: a systematic review and meta-analysis. Lancet.
68 U.S. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research. (2008). Guidance for industry diabetes mellitus: Developing drugs and therapeutic biologics for treatment and prevention.
69 Higgins JP, Green S. (2011). Section 8. Assessing risk of bias in included studies.
70 Wells GA, Shea B, O'connell D, et al. (2000). The Newcastle-Ottawa scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses.
71 Norman GR, Sloan JA, Wyrwich KW. (2003). Interpretation of changes in health-related quality of life: the remarkable universality of half a standard deviation. Med Care.
72 Revicki D, Hays RD, Cella D, et al. (2008). Recommended methods for determining responsiveness and minimally important differences for patient-reported outcomes. J Clin Epidemiol.
73 Sidik K, Jonkman JN. (2002). A simple confidence interval for meta-analysis. Stat Med.
74 Inthout J, Ioannidis JP, Borm GF. (2014). The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC Med Res Methodol.
75 Cornell JE, Mulrow CD, Localio R, et al. (2014). Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med.
76 Higgins JP, Thompson SG. (2002). Quantifying heterogeneity in a meta-analysis. Stat Med.
77 Deeks JJ, Higgins JPT, Altman DG. (2008). Analysing data and undertaking meta-analysis. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions.
78 Egger M, Davey Smith G, Schneider M, et al. (1997). Bias in meta-analysis detected by a simple, graphical test. BMJ.
79 Lu G, Ades AE. (2004). Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med.
80 Salanti G. (2012). Indirect and mixed-treatment comparison, network, or multiple-treatments meta-analysis: many names, many benefits, many concerns for the next generation evidence synthesis tool. Res Synth Methods.
81 Veroniki AA, Vasiliadis HS, Higgins JP, et al. (2013). Evaluation of inconsistency in networks of interventions. Int J Epidemiol.
82 Amsberg S, Anderbro T, Wredling R, et al. (2009). A cognitive behavior therapy-based intervention among poorly controlled adult type 1 diabetes patients-a randomized controlled trial. Patient Educ Couns.
83 Anderson BJ, Brackett J, Ho J, et al. (1999). An office-based intervention to maintain parent-adolescent teamwork in diabetes management. Impact on parent involvement, family conflict, and subsequent glycemic control. Diabetes Care.
84 Boardway RH, Delamater AM, Tomakowsky J, et al. (1993). Stress management training for adolescents with diabetes. J Pediatr Psychol.
85 Christie D, Thompson R, Sawtell M, et al. (2014). Structured, intensive education maximising engagement, motivation and long-term change for children and young people with diabetes: a cluster randomised controlled trial with integral process and economic evaluation - the CASCADE study. Health Technol Assess.
86 Cook S, Herold K, Edidin DV, et al. (2002). Increasing problem solving in adolescents with type 1 diabetes: the CHOICES diabetes program. Diabetes Educ.
87 Ellis DA, Naar-King S, Chen X, et al. (2012). Multisystemic therapy compared to telephone support for youth with poorly controlled diabetes: findings from a randomized controlled trial. Ann Behav Med.
88 Ellis DA, Templin T, Naar-King S, et al. (2007). Multisystemic therapy for adolescents with poorly controlled type I diabetes: stability of treatment effects in a randomized controlled trial. J Consult Clin Psychol.
89 Franklin VL, Waller A, Pagliari C, et al. (2006). A randomized controlled trial of sweet talk, a text-messaging system to support young people with diabetes. Diabet Med.
90 Freeman KA, Duke DC, Harris MA. (2013). Behavioral health care for adolescents with poorly controlled diabetes via Skype: does working alliance remain intact?. J Diabetes Sci Technol.
91 Hermanns N, Kulzer B, Ehrmann D, et al. (2013). The effect of a diabetes education programme (PRIMAS) for people with type 1 diabetes: results of a randomized trial. Diabetes Res Clin Pract.
92 Holmes CS, Chen R, Mackey E, et al. (2014). Randomized clinical trial of clinic-integrated, low-intensity treatment to prevent deterioration of disease care in adolescents with type 1 diabetes. Diabetes Care.
93 Husted GR, Thorsteinsson B, Esbensen BA, et al. (2014). Effect of guided self-determination youth intervention integrated into outpatient visits versus treatment as usual on glycemic control and life skills: a randomized clinical trial in adolescents with type 1 diabetes. Trials.
94 Ismail K, Thomas SM, Maissi E, et al. (2008). Motivational enhancement therapy with and without cognitive behavior therapy to treat type 1 diabetes: a randomized trial. Ann Intern Med.
95 Karlsen B, Idsoe T, Dirdal I, et al. (2004). Effects of a group-based counselling programme on diabetes-related stress, coping, psychological well-being and metabolic control in adults with type 1 or type 2 diabetes. Patient Educ Couns.
96 Katz ML, Volkening LK, Butler DA, et al. (2014). Family-based psychoeducation and care ambassador intervention to improve glycemic control in youth with type 1 diabetes: a randomized trial. Pediatr Diabetes.
97 Kichler JC, Kaugars AS, Marik P, et al. (2013). Effectiveness of groups for adolescents with type 1 diabetes mellitus and their parents. Fam Syst Health.
98 Laffel LM, Vangsness L, Connell A, et al. (2003). Impact of ambulatory, family-focused teamwork intervention on glycemic control in youth with type 1 diabetes. J Pediatr.
99 Lehmkuhl HD, Storch EA, Cammarata C, et al. (2010). Telehealth behavior therapy for the management of type 1 diabetes in adolescents. J Diabetes Sci Technol.
100 Mcnabb WL, Quinn MT, Murphy DM, et al. (1994). Increasing children's responsibility for diabetes self-care: the In Control study. Diabetes Educ.
101 Murphy HR, Wadham C, Rayman G, et al. (2007). Approaches to integrating paediatric diabetes care and structured education: experiences from the families, adolescents, and children's teamwork study (FACTS). Diabet Med.
102 Murphy HR, Wadham C, Hassler-Hurst J, et al. (2012). Randomized trial of a diabetes self-management education and family teamwork intervention in adolescents with type 1 diabetes. Diabet Med.
103 Nansel TR, Iannotti RJ, Simons-Morton BG, et al. (2007). Diabetes personal trainer outcomes: short-term and 1-year outcomes of a diabetes personal trainer intervention among youth with type 1 diabetes. Diabetes Care.
104 Nansel TR, Iannotti RJ, Liu A. (2012). Clinic-integrated behavioral intervention for families of youth with type 1 diabetes: randomized clinical trial. Pediatrics.
105 Perry TL, Mann JI, Lewis-Barned NJ, et al. (1997). Lifestyle intervention in people with insulin-dependent diabetes mellitus (IDDM). Eur J Clin Nutr.
106 Viklund G, Ortqvist E, Wikblad K. (2007). Assessment of an empowerment education programme. A randomized study in teenagers with diabetes. Diabet Med.
107 Weinger K, Beverly EA, Lee Y, et al. (2011). The effect of a structured behavioral intervention on poorly controlled diabetes: a randomized controlled trial. Arch Intern Med.
108 Wysocki T, Harris MA, Buckloh LM, et al. (2007). Randomized trial of behavioral family systems therapy for diabetes: maintenance of effects on diabetes outcomes in adolescents. Diabetes Care.
109 Zoffmann V, Lauritzen T. (2006). Guided self-determination improves life skills with type 1 diabetes and A1c in randomized controlled trial. Patient Educ Couns.
110 Mayer-Davis EJ, Seid M, Crandell J, et al. (2014). Flexible lifestyles for youth (FL3X) behavioural intervention for at-risk adolescents with type 1 diabetes: a randomized pilot and feasibility trial. Diabet Med.
111 Serlachius AS, Scratch SE, Northam EA, et al. (2014). A randomized controlled trial of cognitive behaviour therapy to improve glycaemic control and psychosocial wellbeing in adolescents with type 1 diabetes. J Health Psychol.
112 Mannucci E, Pala L, Rotella CM. (2005). Long-term interactive group education for type 1 diabetic patients. Acta Diabetol.
113 Forlani G, Zannoni C, Tarrini G, et al. (2006). An empowerment-based educational program improves psychological well-being and health-related quality of life in type 1 diabetes. J Endocrinol Invest.
114 Thomas-Dobersen DA, Butler-Simon N, Fleshner M. (1993). Evaluation of a weight management intervention program in adolescents with insulin-dependent diabetes mellitus. J Am Diet Assoc.
115 Viner RM, Christie D, Taylor V, et al. (2003). Motivational/solution-focused intervention improves HbA1c in adolescents with type 1 diabetes: a pilot study. Diabet Med.
116 Amsberg S, Anderbro T, Wredling R, et al. (2009). Experience from a behavioural medicine intervention among poorly controlled adult type 1 diabetes patients. Diabetes Res Clin Pract.
117 Ellis DA, Frey MA, Naar-King S, et al. (2005). Use of multisystemic therapy to improve regimen adherence among adolescents with type 1 diabetes in chronic poor metabolic control: a randomized controlled trial. Diabetes Care.
118 Ellis DA, Naar-King S, Frey M, et al. (2004). Use of multisystemic therapy to improve regimen adherence among adolescents with type 1 diabetes in poor metabolic control: a pilot investigation. J Clin Psychol Med Settings.
119 Ellis DA, Naar-King S, Frey M, et al. (2005). Multisystemic treatment of poorly controlled type 1 diabetes: effects on medical resource utilization. J Pediatr Psychol.
120 Ismail K, Maissi E, Thomas S, et al. (2010). A randomised controlled trial of cognitive behaviour therapy and motivational interviewing for people with type 1 diabetes mellitus with persistent sub-optimal glycaemic control: a diabetes and psychological therapies (ADAPT) study. Health Technol Assess.
121 Nansel TR, Anderson BJ, Laffel LMB, et al. (2009). A multisite trial of a clinic-integrated intervention for promoting family management of pediatric type 1 diabetes: feasibility and design. Pediatr Diabetes.
122 Nansel TR, Iannotti RJ, Simons-Morton BG, et al. (2009). Long-term maintenance of treatment outcomes: diabetes personal trainer intervention for youth with type 1 diabetes. Diabetes Care.
123 Patel A, Maissi E, Chang HC, et al. (2011). Motivational enhancement therapy with and without cognitive behaviour therapy for type 1 diabetes: economic evaluation from a randomized controlled trial. Diabet Med.
124 Ridge K, Bartlett J, Cheah Y, et al. (2012). Do the effects of psychological treatments on improving glycemic control in type 1 diabetes persist over time? A long-term follow-up of a randomized controlled trial. Psychosom Med.
125 Wysocki T, Harris MA, Buckloh LM, et al. (2006). Effects of behavioral family systems therapy for diabetes on adolescents' family relationships, treatment adherence, and metabolic control. J Pediatr Psychol.
126 Toobert DJ, Hampson SE, Glasgow RE. (2000). The summary of diabetes self-care activities measure: results from 7 studies and a revised scale. Diabetes Care.
127 Harris MA, Wysocki T, Sadler M, et al. (2000). Validation of a structured interview for the assessment of diabetes self-management. Diabetes Care.
128 Snoek FJ, Van Der Ven NC, Lubach CH, et al. (2001). Effects of cognitive behavioural group training (CBGT) in adult patients with poorly controlled insulin-dependent (type 1) diabetes: a pilot study. Patient Educ Couns.
129 Iannotti RJ, Nansel TR, Schneider S, et al. (2006). Assessing regimen adherence of adolescents with type 1 diabetes. Diabetes Care.
130 De Wit M, Pouwer F, Gemke RJ, et al. (2007). Validation of the who-5 well-being index in adolescents with type 1 diabetes. Diabetes Care.
131 Varni JW, Burwinkle TM, Jacobs JR, et al. (2003). The PEDSQL in type 1 and type 2 diabetes: reliability and validity of the pediatric quality of life inventory generic core scales and type 1 diabetes module. Diabetes Care.
132 Bradley C. (2000). The 12-item well-being questionnaire: origins, current stage of development, and availability. Diabetes Care.
133 Mannucci E, Ricca V, Bardini G, et al. (1996). Well-being enquiry for diabetics: a new measure of diabetes-related quality of life. Diabetes, Nutrition and Metabolism.
134 Polonsky WH, Anderson BJ, Lohrer PA, et al. (1995). Assessment of diabetes-related distress. Diabetes Care.
135 Adachi M, Yamaoka K, Watanabe M, et al. (2013). Effects of lifestyle education program for type 2 diabetes patients in clinics: a cluster randomized controlled trial. BMC Public Health.
136 Adolfsson ET, Walker-Engstrom ML, Smide B, et al. (2007). Patient education in type 2 diabetes: a randomized controlled 1-year follow-up study. Diabetes Res Clin Pract.
137 Agurs-Collins TD, Kumanyika SK, Ten Have TR, et al. (1997). A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care.
138 Amoako E, Skelly AH, Rossen EK. (2008). Outcomes of an intervention to reduce uncertainty among African American women with diabetes. West J Nurs Res.
139 Anderson DR, Christison-Lagay J, Villagra V, et al. (2010). Managing the space between visits: a randomized trial of disease management for diabetes in a community health center. J Gen Intern Med.
140 Anderson RM, Funnell MM, Butler PM, et al. (1995). Patient empowerment. Results of a randomized controlled trial. Diabetes Care.
141 Anderson RM, Funnell MM, Nwankwo R, et al. (2005). Evaluating a problem-based empowerment program for African Americans with diabetes: results of a randomized controlled trial. Ethn Dis.
142 Anderson RM, Funnell MM, Aikens JE, et al. (2009). Evaluating the efficacy of an empowerment-based self-management consultant intervention: results of a two-year randomized controlled trial. Ther Patient Educ.
143 Anderson-Loftin W, Barnett S, Bunn P, et al. (2005). Soul Food Light: culturally competent diabetes education. Diabetes Educ.
144 Baksi AK, Al-Mrayat M, Hogan D, et al. (2008). Peer advisers compared with specialist health professionals in delivering a training programme on self-management to people with diabetes: a randomized controlled trial. Diabet Med.
145 Barratt R, Frost G, Millward DJ, et al. (2008). A randomised controlled trial investigating the effect of an intensive lifestyle intervention v. standard care in adults with type 2 diabetes immediately after initiating insulin therapy. Br J Nutr.
146 Beverly EA, Fitzgerald SM, Brooks KM, et al. (2013). Impact of reinforcement of diabetes self-care on poorly controlled diabetes: a randomized controlled trial. Diabetes Educ.
147 Bond GE, Burr R, Wolf FM, et al. (2007). The effects of a web-based intervention on the physical outcomes associated with diabetes among adults age 60 and older: a randomized trial. Diabetes Technol Ther.
148 Bozzetto L, Annuzzi G, Costabile G, et al. (2014). A cho/fibre diet reduces and a mufa diet increases postprandial lipaemia in type 2 diabetes: no supplementary effects of low-volume physical training. Acta Diabetol.
149 Bradshaw BG, Richardson GE, Kumpfer K, et al. (2007). Determining the efficacy of a resiliency training approach in adults with type 2 diabetes. Diabetes Educ.
150 Brown SA, Blozis SA, Kouzekanani K, et al. (2005). Dosage effects of diabetes self-management education for Mexican Americans: the Starr county border health initiative. Diabetes Care.
151 Brown SA, Garcia AA, Kouzekanani K, et al. (2002). Culturally competent diabetes self-management education for Mexican Americans: the Starr county border health initiative. Diabetes Care.
152 Brown SA, Garcia AA, Winter M, et al. (2011). Integrating education, group support, and case management for diabetic Hispanics. Ethn Dis.
153 Castejon AM, Calderon JL, Perez A, et al. (2013). A community-based pilot study of a diabetes pharmacist intervention in Latinos: impact on weight and hemoglobin a1c. J Health Care Poor Underserved.
154 Chan JC, Sui Y, Oldenburg B, et al. (2014). Effects of telephone-based peer support in patients with type 2 diabetes mellitus receiving integrated care: a randomized clinical trial. JAMA Intern Med.
155 Chan LS. (2012). Chronic disease self-management in Hong Kong Chinese older adults living in the community. Dissertation Abstracts International: Section B: The Sciences and Engineering.
156 Cheong SH, Mccargar LJ, Paty BW, et al. (2009). The First Step First Bite program: guidance to increase physical activity and daily intake of low-glycemic index foods. J Am Diet Assoc.
157 Clark M, Hampson SE, Avery L, et al. (2004). Effects of a tailored lifestyle self-management intervention in patients with type 2 diabetes. Br J Health Psychol.
158 Cooper H, Booth K, Gill G. (2008). A trial of empowerment-based education in type 2 diabetes-global rather than glycaemic benefits. Diabetes Res Clin Pract.
159 Corkery E, Palmer C, Foley ME, et al. (1997). Effect of a bicultural community health worker on completion of diabetes education in a Hispanic population. Diabetes Care.
160 Cramer JS, Sibley RF, Bartlett DP, et al. (2007). An adaptation of the diabetes prevention program for use with high-risk, minority patients with type 2 diabetes. Diabetes Educ.
161 Dasgupta K, Grover SA, Da Costa D, et al. (2006). Impact of modified glucose target and exercise interventions on vascular risk factors. Diabetes Res Clin Pract.
162 Davis RM, Hitch AD, Salaam MM, et al. (2010). Telehealth improves diabetes self-management in an underserved community: diabetes telecare. Diabetes Care.
163 Deakin TA, Cade JE, Williams R, et al. (2006). Structured patient education: the diabetes X-PERT programme makes a difference. Diabet Med.
164 D'Eramo Melkus G, Chyun D, Vorderstrasse A, et al. (2010). The effect of a diabetes education, coping skills training, and care intervention on physiological and psychosocial outcomes in black women with type 2 diabetes. Biol Res Nurs.
165 Dunstan DW, Mori TA, Puddey IB, et al. (1997). The independent and combined effects of aerobic exercise and dietary fish intake on serum lipids and glycemic control in NIDDM: a randomized controlled study. Diabetes Care.
166 Dunstan DW, Daly RM, Owen N, et al. (2005). Home-based resistance training is not sufficient to maintain improved glycemic control following supervised training in older individuals with type 2 diabetes. Diabetes Care.
167 Eakin EG, Winkler EA, Dunstan DW, et al. (2014). Living Well with Diabetes: 24-month outcomes from a randomized trial of telephone-delivered weight loss and physical activity intervention to improve glycemic control. Diabetes Care.
168 Fisher L, Hessler D, Glasgow RE, et al. (2013). Redeem: a pragmatic trial to reduce diabetes distress. Diabetes Care.
169 Foster GD, Borradaile KE, Vander Veur SS, et al. (2009). The effects of a commercially available weight loss program among obese patients with type 2 diabetes: a randomized study. Postgrad Med.
170 Foster GD, Wadden TA, Lagrotte CA, et al. (2013). A randomized comparison of a commercially available portion-controlled weight-loss intervention with a diabetes self-management education program. Nutr Diabetes.
171 Frosch DL, Uy V, Ochoa S, et al. (2011). Evaluation of a behavior support intervention for patients with poorly controlled diabetes. Arch Intern Med.
172 Gagliardino JJ, Arrechea V, Assad D, et al. (2013). Type 2 diabetes patients educated by other patients perform at least as well as patients trained by professionals. Diabetes Metab Res Rev.
173 Gagliardino JJ, Lapertosa S, Pfirter G, et al. (2013). Clinical, metabolic and psychological outcomes and treatment costs of a prospective randomized trial based on different educational strategies to improve diabetes care (PRODIACOR). Diabet Med.
174 Giannopoulou I, Fernhall B, Carhart R, et al. (2005). Effects of diet and/or exercise on the adipocytokine and inflammatory cytokine levels of postmenopausal women with type 2 diabetes. Metabolism.
175 Glasgow RE, Kurz D, King D, et al. (2012). Twelve-month outcomes of an internet-based diabetes self-management support program. Patient Educ Couns.
176 Glasgow RE, Strycker LA, King DK, et al. (2006). Robustness of a computer-assisted diabetes self-management intervention across patient characteristics, healthcare settings, and intervention staff. Am J Manag Care.
177 Glasgow RE, Nutting PA, Toobert DJ, et al. (2006). Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illn.
178 Goudswaard AN, Stolk RP, Zuithoff NP, et al. (2004). Long-term effects of self-management education for patients with type 2 diabetes taking maximal oral hypoglycaemic therapy: a randomized trial in primary care. Diabet Med.
179 Hawkins SY. (2010). Improving glycemic control in older adults using a videophone motivational diabetes self-management intervention. Res Theory Nurs Pract.
180 Hendricks LE, Hendricks RT. (2000). The effect of diabetes self-management education with frequent follow-up on the health outcomes of African American men. Diabetes Educ.
181 Hermanns N, Kulzer B, Maier B, et al. (2012). The effect of an education programme (MEDIAS 2 ICT) involving intensive insulin treatment for people with type 2 diabetes. Patient Educ Couns.
182 Hill-Briggs F, Lazo M, Peyrot M, et al. (2011). Effect of problem-solving-based diabetes self-management training on diabetes control in a low income patient sample. J Gen Intern Med.
183 Holtrop JS, Hickner J, Dosh S, et al. (2002). “Sticking to It-Diabetes Mellitus”: a pilot study of an innovative behavior change program for women with type 2 diabetes. Am J Health Educ.
184 Huisman S, De Gucht V, Maes S, et al. (2009). Self-regulation and weight reduction in patients with type 2 diabetes: a pilot intervention study. Patient Educ Couns.
185 Izquierdo RE, Knudson PE, Meyer S, et al. (2003). A comparison of diabetes education administered through telemedicine versus in person. Diabetes Care.
186 Johnson ST, Bell GJ, Mccargar LJ, et al. (2009). Improved cardiovascular health following a progressive walking and dietary intervention for type 2 diabetes. Diabetes Obes Metab.
187 Jones H, Edwards L, Vallis TM, et al. (2003). Changes in diabetes self-care behaviors make a difference in glycemic control: the diabetes stages of change (DISC) study. Diabetes Care.
188 Keyserling TC, Samuel-Hodge CD, Ammerman AS, et al. (2002). A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care.
189 Kim MT, Han HR, Song HJ, et al. (2009). A community-based, culturally tailored behavioral intervention for Korean Americans with type 2 diabetes. Diabetes Educ.
190 Kim SH, Lee SJ, Kang ES, et al. (2006). Effects of lifestyle modification on metabolic parameters and carotid intima-media thickness in patients with type 2 diabetes mellitus. Metabolism.
191 Koo BK, Han KA, Ahn HJ, et al. (2010). The effects of total energy expenditure from all levels of physical activity vs. physical activity energy expenditure from moderate-to-vigorous activity on visceral fat and insulin sensitivity in obese type 2 diabetic women. Diabet Med.
192 Kulzer B, Hermanns N, Reinecker H, et al. (2007). Effects of self-management training in type 2 diabetes: a randomized, prospective trial. Diabet Med.
193 Lee A, Siu CF, Leung KT, et al. (2011). General practice and social service partnership for better clinical outcomes, patient self efficacy and lifestyle behaviours of diabetic care: randomised control trial of a chronic care model. Postgrad Med J.
194 Lorig K, Ritter PL, Laurent DD, et al. (2010). Online diabetes self-management program: a randomized study. Diabetes Care.
195 Lorig K, Ritter PL, Villa F, et al. (2008). Spanish diabetes self-management with and without automated telephone reinforcement: two randomized trials. Diabetes Care.
196 Lorig K, Ritter PL, Villa FJ, et al. (2009). Community-based peer-led diabetes self-management: a randomized trial. Diabetes Educ.
197 Lujan J, Ostwald SK, Ortiz M. (2007). Promotora diabetes intervention for Mexican Americans. Diabetes Educ.
198 Lynch EB, Liebman R, Ventrelle J, et al. (2014). A self-management intervention for African Americans with comorbid diabetes and hypertension: a pilot randomized controlled trial. Prev Chronic Dis.
199 Mandel SE, Davis BA, Secic M. (2013). Effects of music therapy and music-assisted relaxation and imagery on health-related outcomes in diabetes education: a feasibility study. Diabetes Educ.
200 Mayer-Davis EJ, D'antonio AM, Smith SM, et al. (2004). Pounds off with empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health.
201 McGowan P. (2011). The efficacy of diabetes patient education and self-management education in type 2 diabetes. Can.
202 Miller CK, Kristeller JL, Headings A, et al. (2014). Comparison of a mindful eating intervention to a diabetes self-management intervention among adults with type 2 diabetes: a randomized controlled trial. Health Educ Behav.
203 Moriyama M, Nakano M, Kuroe Y, et al. (2009). Efficacy of a self-management education program for people with type 2 diabetes: results of a 12 month trial. Jpn J Nurs Sci.
204 Muchmore DB, Springer J, Miller M. (1994). Self-monitoring of blood glucose in overweight type 2 diabetic patients. Acta Diabetol.
205 Murrock CJ, Higgins PA, Killion C. (2009). Dance and peer support to improve diabetes outcomes in African American women. Diabetes Educ.
206 Nishita C, Cardazone G, Uehara DL, et al. (2013). Empowered diabetes management: life coaching and pharmacist counseling for employed adults with diabetes. Health Educ Behav.
207 Palmas W, Findley SE, Mejia M, et al. (2014). Results of the Northern Manhattan diabetes community outreach project: a randomized trial studying a community health worker intervention to improve diabetes care in Hispanic adults. Diabetes Care.
208 Philis-Tsimikas A, Fortmann A, Lleva-Ocana L, et al. (2011). Peer-led diabetes education programs in high-risk Mexican Americans improve glycemic control compared with standard approaches: a Project Dulce promotora randomized trial. Diabetes Care.
209 Plotnikoff RC, Pickering MA, Glenn N, et al. (2011). The effects of a supplemental, theory-based physical activity counseling intervention for adults with type 2 diabetes. J Phys Act Health.
210 Prezio EA, Cheng D, Balasubramanian BA, et al. (2013). Community diabetes education (CODE) for uninsured Mexican Americans: a randomized controlled trial of a culturally tailored diabetes education and management program led by a community health worker. Diabetes Res Clin Pract.
211 Reaney M, Zorzo EG, Golay A, et al. (2013). Impact of Conversation Map education tools versus regular care on diabetes-related knowledge of people with type 2 diabetes: a randomized, controlled study. Diabetes Spectrum.
212 Rickheim PL, Weaver TW, Flader JL, et al. (2002). Assessment of group versus individual diabetes education: a randomized study. Diabetes Care.
213 Ridgeway NA, Harvill DR, Harvill LM, et al. (1999). Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. South Med J.
214 Rock CL, Flatt SW, Pakiz B, et al. (2014). Weight loss, glycemic control, and cardiovascular disease risk factors in response to differential diet composition in a weight loss program in type 2 diabetes: a randomized controlled trial. Diabetes Care.
215 Rosal MC, Olendzki B, Reed GW, et al. (2005). Diabetes self-management among low-income Spanish-speaking patients: a pilot study. Ann Behav Med.
216 Rosal MC, Ockene IS, Restrepo A, et al. (2011). Randomized trial of a literacy-sensitive, culturally tailored diabetes self-management intervention for low-income Latinos: Latinos en Control. Diabetes Care.
217 Rothschild SK, Martin MA, Swider SM, et al. (2014). Mexican American trial of community health workers: a randomized controlled trial of a community health worker intervention for Mexican Americans with type 2 diabetes mellitus. Am J Public Health.
218 Ruggiero L, Moadsiri A, Butler P, et al. (2010). Supporting diabetes self-care in underserved populations: a randomized pilot study using medical assistant coaches. Diabetes Educ.
219 Ruggiero L, Riley BB, Hernandez R, et al. (2014). Medical assistant coaching to support diabetes self-care among low-income racial/ethnic minority populations: randomized controlled trial. West J Nurs Res.
220 Sacco WP, Malone JI, Morrison AD, et al. (2009). Effect of a brief, regular telephone intervention by paraprofessionals for type 2 diabetes. J Behav Med.
221 Salinero-Fort MA, Carrillo-De SPE, Arrieta-Blanco FJ, et al. (2011). Effectiveness of precede model for health education on changes and level of control of HbA1c, blood pressure, lipids, and body mass index in patients with type 2 diabetes mellitus. BMC Public Health.
222 Samuel-Hodge CD, Keyserling TC, Park S, et al. (2009). A randomized trial of a church-based diabetes self-management program for African Americans with type 2 diabetes. Diabetes Educ.
223 Sarkadi A, Rosenqvist U. (2004). Experience-based group education in type 2 diabetes: a randomised controlled trial. Patient Educ Couns.
224 Sevick MA, Korytkowski M, Stone RA, et al. (2012). Biophysiologic outcomes of the enhancing adherence in type 2 diabetes (ENHANCE) trial. J Acad Nutr Diet.
225 Shibayama T, Kobayashi K, Takano A, et al. (2007). Effectiveness of lifestyle counseling by certified expert nurse of Japan for non-insulin-treated diabetic outpatients: a 1-year randomized controlled trial. Diabetes Res Clin Pract.
226 Sigurdardottir AK, Benediktsson R, Jonsdottir H. (2009). Instruments to tailor care of people with type 2 diabetes. J Adv Nurs.
227 Siminerio L, Ruppert KM, Gabbay RA. (2013). Who can provide diabetes self-management support in primary care? Findings from a randomized controlled trial. Diabetes Educ.
228 Sinclair KA, Makahi EK, Shea-Solatorio C, et al. (2013). Outcomes from a diabetes self-management intervention for native Hawaiians and Pacific people: partners in care. Ann Behav Med.
229 Sixta CS, Ostwald S. (2008). Texas-Mexico border intervention by promotores for patients with type 2 diabetes. Diabetes Educ.
230 Skelly AH, Carlson J, Leeman J, et al. (2009). Controlled trial of nursing interventions to improve health outcomes of older African American women with type 2 diabetes. Nurs Res.
231 Skelly AH, Carlson JR, Leeman J, et al. (2005). Symptom-focused management for African American women with type 2 diabetes: a pilot study. Appl Nurs Res.
232 Smith DE, Heckemeyer CM, Kratt PP, et al. (1997). Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM. A pilot study. Diabetes Care.
233 Spencer MS, Rosland AM, Kieffer EC, et al. (2011). Effectiveness of a community health worker intervention among African American and Latino adults with type 2 diabetes: a randomized controlled trial. Am J Public Health.
234 Sperl-Hillen J, Beaton S, Fernandes O, et al. (2013). Are benefits from diabetes self-management education sustained?. Am J Manag Care.
235 Steed L, Lankester J, Barnard M, et al. (2005). Evaluation of the UCL diabetes self-management programme (UCL-DSMP): a randomized controlled trial. J Health Psychol.
236 Sung K, Bae S. (2012). Effects of a regular walking exercise program on behavioral and biochemical aspects in elderly people with type II diabetes. Nurs Health Sci.
237 Tang TS, Funnell M, Sinco B, et al. (2014). Comparative effectiveness of peer leaders and community health workers in diabetes self-management support: results of a randomized controlled trial. Diabetes Care.
238 Thoolen B, De Ridder D, Bensing J, et al. (2007). Effectiveness of a self-management intervention in patients with screen-detected type 2 diabetes. Diabetes Care.
239 Toobert DJ, Glasgow RE, Strycker LA, et al. (2003). Biologic and quality-of-life outcomes from the Mediterranean Lifestyle Program: a randomized clinical trial. Diabetes Care.
240 Toobert DJ, Strycker LA, King DK, et al. (2011). Long-term outcomes from a multiple-risk-factor diabetes trial for Latinas: Viva Bien!. Transl Behav Med.
241 Trief P, Sandberg JG, Ploutz-Snyder R, et al. (2011). Promoting couples collaboration in type 2 diabetes: the Diabetes Support Project pilot data. Fam Syst Health.
242 Tucker CM, Lopez MT, Campbell K, et al. (2014). The effects of a culturally sensitive, empowerment-focused, community-based health promotion program on health outcomes of adults with type 2 diabetes. J Health Care Poor Underserved.
243 Utz SW, Williams IC, Jones R, et al. (2008). Culturally tailored intervention for rural African Americans with type 2 diabetes. Diabetes Educ.
244 Vadstrup ES, Frolich A, Perrild H, et al. (2011). Effect of a group-based rehabilitation programme on glycaemic control and cardiovascular risk factors in type 2 diabetes patients: the Copenhagen Type 2 Diabetes Rehabilitation Project. Patient Educ Couns.
245 Vazquez IM, Millen B, Bissett L, et al. (1998). Buena Alimentacion, Buena Salud: a preventive nutrition intervention in Caribbean Latinos with type 2 diabetes. Am J Health Promot.
246 Vincent D, Pasvogel A, Barrera L. (2007). A feasibility study of a culturally tailored diabetes intervention for Mexican Americans. Biol Res Nurs.
247 Walker EA, Shmukler C, Ullman R, et al. (2011). Results of a successful telephonic intervention to improve diabetes control in urban adults: a randomized trial. Diabetes Care.
248 Welch G, Zagarins SE, Feinberg RG, et al. (2011). Motivational interviewing delivered by diabetes educators: does it improve blood glucose control among poorly controlled type 2 diabetes patients?. Diabetes Res Clin Pract.
249 Welschen LMC, Van Oppen P, Bot SDM, et al. (2013). Effects of a cognitive behavioural treatment in patients with type 2 diabetes when added to managed care: a randomised controlled trial. J Behav Med.
250 West DS, Dilillo V, Bursac Z, et al. (2007). Motivational interviewing improves weight loss in women with type 2 diabetes. Diabetes Care.
251 Wierenga ME. (1994). Life-style modification for weight control to improve diabetes health status. Patient Educ Couns.
252 Wing RR, Bolin P, Brancati FL, et al. (2013). Cardiovascular effects of intensive lifestyle intervention in type 2 diabetes. N Engl J Med.
253 Wolever RQ, Dreusicke M, Fikkan J, et al. (2010). Integrative health coaching for patients with type 2 diabetes: a randomized clinical trial. Diabetes Educ.
254 Wolf AM, Conaway MR, Crowther JQ, et al. (2004). Translating lifestyle intervention to practice in obese patients with type 2 diabetes: improving control with activity and nutrition (ICAN) study. Diabetes Care.
255 Yoo JS, Lee SJ, Lee HC, et al. (2007). The effect of a comprehensive lifestyle modification program on glycemic control and body composition in patients with type 2 diabetes. Asian Nurs Res.
256 Zgibor J, Piatt G. (2013). Project SEED: support, education and evaluation in diabetes.
257 Chlebowy DO, El-Mallakh P, Myers J, et al. (2014). Motivational interviewing to improve diabetes outcomes in African Americans adults with diabetes. West J Nurs Res.
258 Edelman D, Dolor RJ, Coffman CJ, et al. (2015). Nurse-led behavioral management of diabetes and hypertension in community practices: a randomized trial. J Gen Intern Med.
259 Varney JE, Weiland TJ, Inder WJ, et al. (2014). Effect of hospital-based telephone coaching on glycaemic control and adherence to management guidelines in type 2 diabetes, a randomised controlled trial. Intern Med J.
260 Yuan C, Lai CW, Chan LW, et al. (2014). The effect of diabetes self-management education on body weight, glycemic control, and other metabolic markers in patients with type 2 diabetes mellitus. J Diabetes Res.
261 Kim SH, Lee SH, Ahn KY, et al. (2014). Effect of lifestyle modification on serum chemerin concentration and its association with insulin sensitivity in overweight and obese adults with type 2 diabetes. Clin Endocrinol (Oxf).
262 Moncrieft AE. (2014). Randomized controlled trial of a behavioral weight loss intervention for primary prevention of renal decline in type 2 diabetics. Dissertation Abstracts International: Section B: The Sciences and Engineering.
263 Sorkin DH, Mavandadi S, Rook KS, et al. (2014). Dyadic collaboration in shared health behavior change: the effects of a randomized trial to test a lifestyle intervention for high-risk Latinas. Health Psychol.
264 Rosal MC, Heyden R, Mejilla R, et al. (2014). A virtual world versus face-to-face intervention format to promote diabetes self-management among African American women: a pilot randomized clinical trial. JMIR Res Protoc.
265 Holmen H, Torbjornsen A, Wahl AK, et al. (2014). A mobile health intervention for self-management and lifestyle change for persons with type 2 diabetes, part 2: one-year results from the Norwegian randomized controlled trial Renewing Health. JMIR MHealth and UHealth.
266 Amoako EP. (2004). Managing uncertainty in diabetes: an intervention for older African-American women.
267 Bond GE, Burr RL, Wolf FM, et al. (2010). The effects of a web-based intervention on psychosocial well-being among adults aged 60 and older with diabetes: a randomized trial. Diabetes Educ.
268 Brown SA, Hanis CL. (1999). Culturally competent diabetes education for Mexican Americans: the Starr county study. Diabetes Educ.
269 Cooper H, Booth K, Gill G. (2003). Using combined research methods for exploring diabetes patient education. Patient Educ Couns.
270 Daly RM, Dunstan DW, Owen N, et al. (2005). Does high-intensity resistance training maintain bone mass during moderate weight loss in older overweight adults with type 2 diabetes?. Osteoporos Int.
271 Davis RM, Hitch AD, Nichols M, et al. (2009). A collaborative approach to the recruitment and retention of minority patients with diabetes in rural community health centers. Contemp Clin Trials.
272 Dunstan DW, Daly RM, Owen N, et al. (2002). High-intensity resistance training improves glycemic control in older patients with type 2 diabetes. Diabetes Care.
273 Glasgow RE, Kurz D, King D, et al. (2010). Outcomes of minimal and moderate support versions of an internet-based diabetes self-management support program. J Gen Intern Med.
274 Gurka MJ, Wolf AM, Conaway MR, et al. (2006). Lifestyle intervention in obese patients with type 2 diabetes: impact of the patient's educational background. Obesity (Silver Spring).
275 King DK, Estabrooks PA, Strycker LA, et al. (2006). Outcomes of a multifaceted physical activity regimen as part of a diabetes self-management intervention. Ann Behav Med.
276 Look Ahead Research Group. (2014). Impact of intensive lifestyle intervention on depression and health-related quality of life in type 2 diabetes: the Look Ahead trial. Diabetes Care.
277 Look Ahead Research Group. (2014). Eight-year weight losses with an intensive lifestyle intervention: the Look Ahead study. Obesity (Silver Spring).
278 Look Ahead Research Group. (2014). Effect of a long-term behavioural weight loss intervention on nephropathy in overweight or obese adults with type 2 diabetes: a secondary analysis of the Look Ahead randomised clinical trial. Lancet Diabetes Endocrinol.
279 Lujan J. (2006). The effectiveness of a promotora-led intervention for Mexican Americans with type 2 diabetes.
280 Miller CK, Kristeller JL, Headings A, et al. (2012). Comparative effectiveness of a mindful eating intervention to a diabetes self-management intervention among adults with type 2 diabetes: a pilot study. J Acad Nutr Diet.
281 Samuel-Hodge CD, Keyserling TC, France R, et al. (2006). A church-based diabetes self-management education program for African Americans with type 2 diabetes. Prev Chronic Dis.
282 Sevick MA, Stone RA, Zickmund S, et al. (2010). Factors associated with probability of personal digital assistant-based dietary self-monitoring in those with type 2 diabetes. J Behav Med.
283 Shreck E, Gonzalez JS, Cohen HW, et al. (2014). Risk perception and self-management in urban, diverse adults with type 2 diabetes: the improving diabetes outcomes study. Int J Behav Med.
284 Sixta CS. (2007). Border intervention by promotores for type 2 diabetes.
285 Spencer MS, Hawkins J, Espitia NR, et al. (2013). Influence of a community health worker intervention on mental health outcomes among low-income Latino and African American adults with type 2 diabetes. Race Soc Probl.
286 Thoolen BJ, De Ridder D, Bensing J, et al. (2009). Beyond Good Intentions: the role of proactive coping in achieving sustained behavioural change in the context of diabetes management. Psychol Health.
287 Toobert DJ, Glasgow RE, Strycker LA, et al. (2007). Long-term effects of the Mediterranean Lifestyle Program: a randomized clinical trial for postmenopausal women with type 2 diabetes. Int J Behav Nutr Phys Act.
288 Toobert DJ, Strycker LA, Barrera MJ, et al. (2011). Outcomes from a multiple risk factor diabetes self-management trial for Latinas: Viva Bien!. Ann Behav Med.
289 Toobert DJ, Strycker LA, Glasgow RE, et al. (2005). Effects of the Mediterranean lifestyle program on multiple risk behaviors and psychosocial outcomes among women at risk for heart disease. Ann Behav Med.
290 Vadstrup ES, Frolich A, Perrild H, et al. (2011). Health-related quality of life and self-related health in patients with type 2 diabetes: effects of group-based rehabilitation versus individual counselling. Health Qual Life Outcomes.
291 Wang ML, Lemon SC, Whited MC, et al. (2014). Who benefits from diabetes self-management interventions? The influence of depression in the Latinos en Control trial. Ann Behav Med.
292 Wolf AM, Siadaty M, Yaeger B, et al. (2007). Effects of lifestyle intervention on health care costs: improving control with activity and nutrition (ICAN). J Am Diet Assoc.
293 Knowler WC, editor. Impact of a lifestyle intervention on diabetes control and microvascular complications American Diabetes Association 73rd Scientific Sessions.
294 Sperl-Hillen J, Beaton S, Fernandes O, et al. (2011). Comparative effectiveness of patient education methods for type 2 diabetes: a randomized controlled trial. Arch Intern Med.
295 Ayling K, Brierley S, Johnson B, et al. (2015). How standard is standard care? Exploring control group outcomes in behaviour change interventions for young people with type 1 diabetes. Psychol Health.
296 Court JM, Cameron FJ, Berg-Kelly K, et al. (2009). Diabetes in adolescence. Pediatr Diabetes.
297 Ingerski LM, Anderson BJ, Dolan LM, et al. (2010). Blood glucose monitoring and glycemic control in adolescence: contribution of diabetes-specific responsibility and family conflict. J Adolesc Health.
298 Schilling LS, Knafl KA, Grey M. (2006). Changing patterns of self-management in youth with type I diabetes. J Pediatr Nurs.
299 Peters A, Laffel L. (2011). Diabetes care for emerging adults: recommendations for transition from pediatric to adult diabetes care systems. Diabetes Care.
300 Duke SaS, Colagiuri S, Colagiuri R. (2009). Individual patient education for people with type 2 diabetes mellitus. Cochrane Database Syst Rev.
301 Herman WH, Dungan KM, Wolffenbuttel BH, et al. (2009). Racial and ethnic differences in mean plasma glucose, hemoglobin A1c, and 1,5-anhydroglucitol in over 2000 patients with type 2 diabetes. J Clin Endocrinol Metab.
302 Nam S, Janson SL, Stotts NA, et al. (2012). Effect of culturally tailored diabetes education in ethnic minorities with type 2 diabetes: a meta-analysis. J Cardiovasc Nurs.
303 Cohen J. (1992). A power primer. Psychological bulletin.
304 Sone H, Tanaka S, Iimuro S, et al. (2010). Long-term lifestyle intervention lowers the incidence of stroke in Japanese patients with type 2 diabetes: a nationwide multicentre randomised controlled trial (the Japan Diabetes Complications Study). Diabetologia.
305 Trento M, Passera P, Bajardi M, et al. (2002). Lifestyle intervention by group care prevents deterioration of type II diabetes: a 4-year randomized controlled clinical trial. Diabetologia.
306 Jaber LA, Halapy H, Fernet M, et al. (1996). Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother.
307 Kim HS, Oh JA. (2003). Adherence to diabetes control recommendations: impact of nurse telephone calls. J Adv Nurs.
308 Moher D, Pham B, Klassen TP, et al. (2000). What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol.