# Methods

The methods for this review of behavioral programs for diabetes mellitus are based on the methods specified in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (Methods Guide).59 The main sections in this chapter reflect the elements of the protocol established for the review.60 The methods and analyses were determined a priori, except where otherwise specified.

## Topic Refinement and Review Protocol

The Centers for Disease Control and Prevention (CDC) are partners with AHRQ in this review. During the topic development and refinement processes, we developed draft versions of the analytic frameworks, Key Questions (KQs), and inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). The processes were guided by the information provided by the topic nominator, a scan of the literature, and discussions with methods and contents experts, and Key Informants (KIs); we worked with CDC and nine KIs during topic refinement. Subsequently, the analytic frameworks, KQs and PICOTs were posted for public comment on AHRQ's Effective Health Care Web site from January 8 through January 27, 2014. After consultation with AHRQ and responding to the public comments, we engaged representatives from CDC and a Technical Expert Panel (TEP)—including two of the KIs—to develop the systematic review protocol. Conference calls and discussions through email were undertaken to review the analytic framework, KQs, PICOTS, and operational definition of a behavioral program (Appendix A), and to gain input on categorizing the interventions based on the various program components and delivery methods. The final protocol was posted on AHRQ's Effective Healthcare Web site on June 12, 2014.^60^ The protocol was registered with the PROSPERO database (No. CRD42014010515) on July 11, 2014.

## Literature Search Strategy

We used the same approach and search strategies for type one diabetes mellitus (T1DM) and type two diabetes mellitus (T2DM). Our research librarian searched the following databases from 1993 to May 2014: Ovid MEDLINE and Ovid MEDLINE® In-Process & Other Non-Indexed Citations, Cochrane Central Register of Controlled Trials via Cochrane Library, EMBASE® via Ovid, CINAHL Plus with Full Text via EBSCOhost, PsycINFO® via Ovid, and PubMed® (2014 only) via the National Center for Biotechnology Information Databases. On January 15, 2015, we performed a search update in all databases except EMBASE, from which none of the previously included studies was exclusively obtained.

We limited the search to prospective controlled studies published in English. Search strategies included a combination of subject headings and keywords for diabetes, behavioral interventions, and diabetes education. We applied a validated search filter for randomized controlled trials (RCTs) and a search filter to identify prospective comparative studies.61 The search strategy was developed in MEDLINE, peer reviewed by a second librarian, and adapted to accommodate the controlled vocabularies and search languages of the other databases. Appendix B presents the full search strategy for each database.

We reviewed the reference lists of relevant systematic reviews and of all included studies. We searched for trials in ClinicialTrials.gov and the World Health Organization International Clinical Trials Registry Platform. We hand searched the conference proceedings from the American Diabetes Association, American Association of Diabetes Educators, National Institute of Diabetes and Digestive and Kidney Diseases, Canadian Diabetes Association, European Association for the Study of Diabetes, International Diabetes Federation, Society of Behavioral Medicine, and International Society for Behavioral Nutrition and Physical Activity from 2011 to 2014 (when available). When a trial protocol or abstract met our screening criteria, we searched online for associated publications and contacted the authors to enquire whether a report was available to undergo full-text screening.

We used EndNote^®^ database (Thomson Reuters, New York, NY) to manage the results of our literature searches.

## Inclusion and Exclusion Criteria

The eligibility criteria are outlined in the PICOTS for T1DM and T2DM for the KQs (Tables 1 and 2). For both T1DM and T2DM, we included studies conducted in the United States or other high-income countries (Appendix C) and published in the English language.62 We included studies conducted in high-income countries because we believed that the results would be more relevant to community health settings in the United States. We included English-language publications because we believed it was unlikely that we would miss important data reported in non-English articles. The earliest publication date for studies was 1993. This date was chosen because of changes to usual care/medical management (the comparator in most cases in this review) resulting from the findings of landmark trials published from this date onwards.20,29,63

Table 1 Inclusion criteria for type 1 diabetes (Key Questions 1–4)

Parameter | Criteria
Population | - Patients with T1DM (any age) who have undergone basic diabetes education
Interventions | - Multicomponent behavioral program that includes at least one of:; - Diabetes self-management education; OR; - Structured dietary intervention (related to any of weight loss, glycemic control, or reducing risk for complications) together with one or more additional components; OR; - Structured exercise/physical activity intervention together with one or more additional components.; - Additional components may include interventions related to: diet or physical activity, behavioral change (including but not limited to: goal setting, problem solving, motivational interviewing, coping skills training, cognitive behavioral therapy strategies), relaxation or stress reduction, blood glucose awareness, medication adherence, or self-monitoring for diabetic complications (foot, eye, and renal tests).; - Repeated provision by one or more trained individuals; - Duration of intervention: minimum 4 weeks
Comparators | - Usual or standard care (i.e., medical management provided to all study participants), an active control (i.e., intervention in addition to usual care but not meeting our operational definition of behavioral program), or another behavioral program; - Delivery methods (personnel, intensity, communication methods etc.) as reported for studies
Outcomes | - Behavioral outcomes; - Self-regulation of insulin based on diet, physical activity, and glucose monitoring results; - Change in physical activity (e.g., volume of activity per week) or fitness (e.g. cardiorespiratory fitness, strength); - Change in dietary or nutrient intake (i.e., energy intake, saturated fat consumption); - Adherence to treatment, including self-monitoring and medication; - Clinical outcomes; - Glycemic control (HbA_1c_); - Change in body composition (i.e., weight, BMI, waist circumference, % body fat); - Episodes of severe hypoglycemia68; - Treatment for hyperglycemia (ketoacidosis); - Control of blood pressure and lipids; - Development or control of depression or anxiety; - Health outcomes; - Quality of life (e.g., validated tools for health-related quality of life, life satisfaction, psychosocial adaptation to illness, patient satisfaction); - Development of micro- and macrovascular complications (i.e., retinopathy, nephropathy, neuropathy, cardiovascular outcomes); - Mortality (all-cause); - Diabetes-related health care utilization; - Hospital admissions; - Length of stay in hospital; - Emergency department admissions; - Visits to specialist clinics; - Program acceptability as measured by participant attrition rates; - Harms from program as reported for studies; - Activity-related injury
Timing | - Any length of postintervention followup
Study design | - Prospective comparative studies using a best evidence approach based on hierarchy of evidence: randomized controlled trials, nonrandomized controlled trials, prospective cohort studies, controlled before-after studies
Settings | - Community health setting (i.e. ambulatory care clinics, outpatient clinics, primary care clinics, family physician clinics, Community Health Centers, Rural Health Centers); - United States or other high-income countries with a very high Human Development Index62
Language | - English

BMI = body mass index; HbA_1c_ = hemoglobin A_1c_; T1DM = type 1 diabetes

Table 2 Inclusion criteria for type 2 diabetes (Key Questions 5 and 6)

Parameter | Criteria
Population | - Adults (≥18 years) with T2DM who have undergone primary diabetes education
Interventions | - Multicomponent behavioral programs that include at least one of:; - Diabetes self-management education; OR; - Structured dietary intervention (related to any of weight loss, glycemic control, or reducing risk for complications) together with one or more additional components; OR; - Structured exercise/physical activity intervention together with one or more additional components.; - Additional components may include interventions related to: diet or physical activity, behavioral change (including but not limited to: goal setting, problem solving, motivational interviewing, coping skills training, cognitive behavioral therapy strategies), relaxation or stress reduction, blood glucose awareness, medication adherence, or self-monitoring for diabetic complications (foot, eye, and renal tests).; - Repeated provision by one or more trained individuals; - Duration of intervention: minimum 4 weeks
Comparators | - Usual or standard care (i.e., medical management provided to all study participants), an active control (i.e. intervention in addition to usual care but not meeting our operational definition of behavioral program), or another behavioral program; - Delivery methods (personnel, intensity, communication methods etc.) as reported for studies
Outcomes | - Behavioral outcomes; - Change in physical activity (e.g., volume of activity per week) or fitness (e.g., cardiorespiratory fitness, strength); - Change in dietary or nutrient intake (i.e., energy intake, saturated fat consumption); - Adherence to medication; - Clinical outcomes; - Glycemic control (HbA_1c_); - Change in body composition (i.e., weight, BMI, waist circumference, % body fat); - Control of blood pressure and lipids; - Sleep apnea or sleep quality; - Development or control of depression or anxiety; - Health outcomes; - Quality of life (e.g., validated tools for health-related quality of life, life satisfaction, psychosocial adaptation to illness, patient satisfaction); - Development of micro- and macrovascular complications (i.e., retinopathy, nephropathy, neuropathy, cardiovascular outcomes); - Mortality (all-cause); - Diabetes-related health care utilization; - Hospital admissions; - Length of stay in hospital; - Emergency department admissions; - Visits to specialist clinics; - Program acceptability as measured by participant attrition rates
Timing | - Any length of postintervention followup
Study design | - Randomized controlled trials
Settings | - Community health setting (i.e., ambulatory care clinics, outpatient clinics, primary care clinics, family physician clinics, Community Health Centers, Rural Health Centers); - United States or other high-income country with a very high Human Development Index62
Language | - English

BMI = body mass index; HbA_1c_ = hemoglobin A_1c_; T2DM = type 2 diabetes

For T1DM, we included prospective comparative studies (i.e., RCTs, nonrandomized controlled trials [non-RCTs], prospective cohort studies, controlled before-after studies).64 For T2DM we included RCTs. RCTs are the gold standard for determining the effectiveness of interventions particularly when there are multiple potential confounding patient and intervention factors that may bias the results.65 Our preliminary searches during topic refinement identified over 400 potentially relevant RCTs involving patients with T2DM and we believed that there would be sufficient trials and variability with respect to program factors to address the relevant KQs. We did not have a minimum sample size for inclusion, or a threshold for extent of incomplete followup or participant attrition.

We included a broad range of comparators to behavioral programs and categorized them as follows. Usual (standard) care control arms consisted of usual medical management (often multidisciplinary and including some form of education) provided to all study participants regardless of study participation; this could be provided by the study investigators or other health care professionals. Because medical care is so diverse between settings, some study arms (i.e., receiving educational pamphlets or an individual session with a dietitian) were classified as usual care even when described by the authors as active control. Interventions that were offered for the purposes of the study and provided content addressing behavior changes, but did not meet our operational definition of a behavioral program, were considered active controls. Examples of active controls include a dietary intervention or a basic education program of short duration or not including behavioral approaches. We categorized some control arms as attention control, when the group received similar contact time as the intervention arm but no intervention hypothesized to promote behavioral change. These arms were grouped with usual care arms for analysis and sensitivity analysis was conducted (i.e., removal of these arms) when the heterogeneity in the meta-analysis was substantial (see Data Synthesis). All trial arms that met our definition of a behavioral program were considered “interventions”; when two intervention arms were compared “head-to-head” we considered this to evaluate their comparative effectiveness.

To help distinguish between the effects of behavioral programs (targeting patient behaviors) and other interventions, we excluded studies where the intervention was a disease/care management program (e.g., consisting of one or more interventions actively adjusting diabetes-related medications, monitoring patient medical data, or coordinating care provision)66 or other quality improvement programs that incorporate strategies targeting health systems or providers.67 This criterion was further refined after the protocol was published. Specifically, usual medical management (usual care) of all study participants needed to be stated by the authors or judged by the reviewers to be similar; for example, studies were excluded if the intervention arm(s) received stricter targets for glycemic control or more intensive medication regimes than the control arm. Additionally, studies investigating behavioral programs as one component of innovative medical care models (e.g. group appointments, pharmaceutical care) were only included if the effect of the behavioral program could be isolated. Other exclusion criteria included: (1) studies focusing exclusively on newly diagnosed patients, who do not represent our target population; (2) reports of studies where the outcomes were not of interest to this review (e.g., short-term effects on glucose sensitivity, C-reactive protein), or when the only difference between the study groups was a factor outside of the review's scope (e.g., two intervention arms differing only by diet composition rather than delivery method, personnel etc.); (3) studies evaluating behavioral programs targeted at hospital inpatients; (4) studies evaluating community-based programs that were not implemented in affiliation with a community health setting (e.g., school-based programs); (5) studies published exclusively in abstract form (e.g., conference abstracts). Where relevant abstracts were identified we searched for a complete report including contacting authors, as needed.

## Study Selection

Two members of the research team independently screened all titles and abstracts (when available) using broad inclusion/exclusion criteria (Tables 1 and 2). We retrieved the full text of any publications marked for inclusion by either reviewer. Two reviewers independently assessed the full texts using a standard form that outlined the inclusion and exclusion criteria (see Figure S1 in the Supplementary File). The reviewers resolved any disagreements through consensus or by consulting a third member of the review team.

We used an internally developed online tool to manage the title and abstract screening and full text review. The results from the full text review were then exported to an EndNote® database. We recorded the principal reason for excluding full text publications that did not satisfy the eligibility criteria.

## Data Extraction

We extracted data directly into the Systematic Review Data Repository (SRDR™). One reviewer extracted data, and a second reviewer checked the data for accuracy and completeness. We resolved disagreements through consensus or by consulting a third member of the review team. We extracted the following data: author identification, year of publication, source of funding, study design, population (i.e., inclusion and exclusion criteria, number of participants enrolled, study withdrawals, duration of followup), baseline characteristics (e.g., age, duration of diabetes, HbA_1c_, race/ethnicity, weight, body mass index), details of the interventions and comparators, and outcomes. When more than one publication reported the results of a single study, we considered the earliest published report of the main outcome data to be the primary publication. We extracted data from the primary publication first and then any additional data reported in the associated publications; this report cites all study results to the primary publication. We only extracted outcome data at or after the end-of-intervention timepoint; interim results prior to the end of any intervention contact were not included. We recorded intention-to-treat results, if possible. Other decision rules were developed for extraction of outcome data: 1) when both subjective and objective assessment was performed for change in dietary or nutrient intake, or physical activity (e.g., exercise duration/intensity via self-report and accelerometer) we only extracted the objective data; and 2) for clinical or health outcomes relying on questionnaires (e.g., depression, anxiety, quality of life) we only extracted data when composite or component scores were provided.

For studies where it was unclear whether patients had T1DM or T2DM, we developed decision rules based on mean age of study population, duration of diabetes, and the description of medical management. In studies where both types of patients were included and results were not reported separately, if more that 75 percent were one type of diabetes we included the study with that disease group.

## Risk of Bias Assessment of Individual Studies

Two reviewers independently assessed the risk of bias (ROB) of the included studies. Discrepancies were resolved through discussion and consensus.

We assessed the internal validity of RCTs and non-RCTs using the Cochrane Risk of Bias tool.69 The tool examines seven domains of potential bias (sequence generation, concealment of allocation, blinding of participants and personnel, blinding of outcome assessment, incomplete outcome data, selective outcome reporting, and “other” sources of data), and a categorization of the overall ROB.

Each domain was rated as having “low,” “unclear (medium),” or “high” ROB. We assessed blinding and incomplete outcome data separately for subjective outcomes (e.g., quality of life) and objective outcomes (e.g., HbA_1c_); we only rated the ROB for those outcomes of interest to this review and on which we report. We reported additional sources of bias, including baseline imbalances and design-specific ROB, in the “other” sources of bias domain.

We created decision rules for consideration of blinding of participants, personnel, and outcome assessors (see Figure S2 in the Supplementary File). Examples which met the criteria for low ROB for these domains include: 1) for participants, when the comparator was an attention control, active control, or another behavioral program, and the authors reported some mechanism for blinding the participants from the study hypothesis; 2) for personnel, if they followed a standard protocol and received structured training in program delivery; and 3) for outcome assessment, double blinding of participant and outcome assessor was deemed not necessary for subjective outcomes if the participants were blinded (as above) and independently completed questionnaires.

The overall ROB assessment was based on the responses to individual domains. If one or more individual domains had a high ROB, we rated the overall score as high ROB. We rated the overall ROB as low only if all components were assessed as having a low risk. In all other situations, the overall ROB was rated as medium.

We assessed the ROB for prospective cohort studies and controlled before-after studies using the Newcastle-Ottawa Scale (Figure S3 in Supplementary File).70 This tool uses a star system to assess methodological quality across three categories: selection of participants, comparability of study groups, and ascertainment of the outcome of interest. The star rating indicates the quality of a study with a maximum assessment of nine. If a study scored eight or nine, we rated the overall ROB as low. We rated the overall risk as medium if the score was between five and seven. For scores below five, the overall ROB was rated as high.

## Data Synthesis

We analyzed data separately for T1DM and T2DM with different approaches for each KQ as outlined below. For each condition we summarized the characteristics of included studies qualitatively and presented important features of the study populations, interventions, and comparators in summary tables. Outcome data are reported in figures of meta-analyses (if pooled) and/or outcomes tables. We calculated mean differences (MD) or standardized mean differences (SMD) for continuous variables, and risk ratios (RR) for dichotomous data. The findings represent differences between the intervention and comparator arm. When possible we used (or computed) change from baseline data; otherwise final values were used. If standard deviations were not given, they were computed from p-values, 95% confidence intervals (95% CIs), z-stats, or t-stats. If computation was not possible they were estimated from upper bound p-values, ranges, inter-quartile ranges, or (as a last resort) by imputation using the largest reported SD from the other studies in the same meta-analysis. When computing standard deviations for change from baseline values, we assumed a correlation of 0.5, unless other information was present in the study that allowed us to compute it more precisely. Results are reported with accompanying 95% CIs.

The focus of our analysis (and for determining which outcomes to grade for strength for evidence for KQs 1 and 2 [see relevant section in this chapter]) rested on outcomes we considered most clinically relevant or important to patients; we refer to these as “key outcomes”. Included in this category were all health outcomes (i.e., quality of life, development of micro- and macrovascular complications, all-cause mortality) and selected behavioral and clinical outcomes (i.e., glycemic control, adherence to diabetes self-management behaviors, change in body composition, change in physical activity or fitness, and change in dietary or nutrient intake). Where guidance from the literature was available, we defined a minimum clinically significant difference (i.e., the smallest difference between groups that can be considered clinically significant); we refer to this in the results and discussion chapters by commenting on whether results were clinically important. For HbA_1c_, we used a difference of 0.4 units in percent HbA_1c_ (e.g., 7.6% vs. 8.0% HbA_1c_), which is based on the value used by the U.S. Food and Drug Administration.68 For quality of life measures and other patient-reported outcomes represented by continuous data, we used a difference of one-half standard deviation (i.e., 0.50 SMD) based on the mean SD from the pooled studies, which has been shown to represent a universal, conservative estimate of a meaningful difference.71,72 For adherence to self-management behaviors, we did not apply a threshold for clinical importance because of poor reporting of the scoring and unknown meaning of a threshold for an optimal number of self-monitoring tests (the most common reporting for this outcome).

With input from the TEP, we categorized various components and delivery mechanisms (e.g., program intensity, method of communication, presence of community engagement) as outlined in Table 3. We separated DSME and DSME plus support into two categories to recognize that the support phase was often (1) of a lower intensity (i.e., less frequent contacts), and (2) focused on different content such as psychosocial support, as compared with the DSME phase. The cut-points used for creating the intensity categories were based on practical considerations. The 10-hour “minimal intensity” limit was based on the current number of hours billable for patients eligible for public healthcare administered by the Centers for Medicare and Medicaid Services in the United States; this was described by our TEP as an important practical limitation on implementing programs having higher intensity. The value of 27 hours was based on what would be considered the lower range of highly intense (e.g., at least weekly 1-hour sessions for 6 months). The categories were used in the summary tables to describe the behavioral program(s) for each study, and for coding the variables used for the regression and network meta-analyses for KQs 3, 5, and 6 (described later in this section). For the network meta-analyses performed for KQs 5 and 6, the categories were used to define groups (nodes) of interventions that were “sufficiently similar” in terms of the factors of interest. Table 3 also indicates that actual values were used for program duration, intensity, and frequency of contacts where suitable (i.e., regression analyses for KQs 3 and 6). When calculating contact hours, we assumed telephone calls (when described in number and serving as more than a reminder/basic followup) would be 10 minutes each if their duration was not reported; this was based on reviewing studies from our preliminary searches that indicated most followup calls were reported as approximately 15 minutes (variable compliance) and that the duration of calls used for providing more substantial content were often not reported. Care was taken to avoid counting time/contacts required solely for research purposes (e.g., outcome assessment). Initially, the program components category included more items (i.e., diet plus additional component, physical activity plus additional component; see Appendix A for operational definitions) but because of very few studies evaluating these categories we collapsed all programs that were not DSME, or DSME plus support, into a “lifestyle” category largely containing programs focusing on diet and physical activity.

Table 3 Categorization of program components and delivery factors

Program Factors | Categories and Description Variables
Program Components^a^ | 1. DSME; 2. DSME + Support: DSME plus a phase to extend program duration and provide support (often clinically focused but may be psychosocial, educational or behavioral); 3. Lifestyle programs: Behavioral programs focused on diet and/or physical activity rather than on diabetes-specific self-management behaviors; may also include other components as long as does not meet the criteria for DSME with emphasis on education/training
Duration of program | No categories; duration (m) was used as a continuous variable for the regression analyses for KQs 3 and 6
Intensity of program-continuous | No categories; intensity (h) was used as a continuous variable for the regression analyses for KQs 3 and 6
Intensity-categorical^a^ (contact hours; where contact hours could not be calculated, we used number of contacts as a proxy) | 1. ≤10h; 2. 11 to 26h (e.g., weekly for up to 6m); 3. ≥27h (allowing for monthly followup for 1yr)
Frequency of contacts | No categories; this was a composite variable combining duration and intensity (h/m); the continuous variable was used for the regression analyses
Method of communication^b^ | 1. In person only; 2. Mixture of in person and technology; 3. All technology with minimal interaction with providers
Method of delivery^c^ | 1. Individual; 2. Mixed individual and group; 3. Group
Delivery personnel^d^ | 1. Delivered entirely by non-health professional (e.g., lay/community health worker, undergraduate students) after training and under some supervision; 2. One health professional for large majority (>75%) of delivery; 3. Provision by multidisciplinary team of health professionals
Degree of tailoring^e^ | 1. None/Minimal – none or only small portion is tailored (e.g., personalized diet prescription in otherwise highly structured lifestyle program or delivery based on flexible hours but same content for all); 2. Moderate/maximum – most of program has content and/or delivery tailoring (e.g., topics are based on needs assessment and delivery timing/duration/location is based participant's schedule/needs/location preferences)
Level and nature of community engagement | 1. Present, e.g., peer delivering program or peer support groups for support stage, use of community resources (infrastructure) for delivery or maintenance stages; 2. Absent, e.g., unreported or provision of information about community resources
Presence of support person^f^ | 1. Family or parent involved in >1 session; 2. No family or parent involvement in sessions

DSME = diabetes self-management education; h = hour; m = month; T1DM = type 1 diabetes mellitus; T2DM = type 2 diabetes mellitus; yr = year

a For network meta-analysis only.

b 2 and 3 were combined for analysis.

c 1 and 2 were combined for analysis.

d 2 and 3 were combined for analysis for KQ 5 and 6.

e Used in summary tables only.

f For studies of youth/adolescents only.

### Synthesis for T1DM (KQs 1–4)

#### KQ 1 Behavioral Programs for T1DM and Behavioral, Clinical, and Health Outcomes; Diabetes-Related Health Care Utilization; and Program Acceptability

For each comparison of interest, we conducted a pairwise meta-analysis when two or more eligible trials were sufficiently similar on the basis of study design, clinical homogeneity of patient populations, interventions, comparators, outcomes, and timepoints. Because we assumed that behavioral programs for T1DM would be sufficiently different when developed for and studied in children and adolescents (“youth”) compared with adults, we present both pooled and subgroup analysis based on age when there was more than one trial in each age category at the relevant timepoint. We used the Hartung-Knapp-Sidik-Jonkman random effects model for all meta-analyses using Stata 11.2 and Excel 2010 software.73-75 We calculated pooled MD, SMD, or RR with corresponding 95% CIs, as appropriate and each weighted by sample size and variance. We analyzed outcomes at different postintervention timepoints using strata: end of active intervention-≤1month, 1-≤6 months, >6-12 months, >12-24 months, and >24 months. If a study included more than one followup timepoint in each strata, we used data from the longer followup. We did not include the results of observational studies in any of the pooled analyses.

Sensitivity analyses (including leave-one-out analyses, assuming a fixed effects model, re-analyses after excluding a group of studies) were undertaken where appropriate (e.g., in the presence of studies with outlying effect sizes, for studies rated as high risk of bias in some domains such as incomplete [<70 percent] outcome data, to examine the effects from combining usual care and attention control groups). Heterogeneity was considered substantial when the I^2^ statistic (the proportion of variation in study estimates attributable to heterogeneity) was greater than 50 percent.76 We explored between-study heterogeneity using subgroup and meta-regression analyses where there were at least 10 studies.77 Planned subgroups are listed in KQs 2 and 6. Publication bias was assessed both visually and quantitatively using Egger's test for the outcome with the greatest amount of data.78

#### KQ 2 Subgroups for Effectiveness in T1DM

For this KQ, we assessed the effects on subgroups for HbA_1c_, which was the outcome reported by the most studies. We searched for subgroup analyses reported by individual trials (i.e., within-study subgroups) that focused on whether a particular behavioral program was more or less effective based on age (children and adolescents [≤18 years], young adults [19-30 years], adults [31-64 years], older adults ≥65 years]), race or ethnicity, socioeconomic status, time since diagnosis (≤1 year vs. >1 year), and baseline level of glycemic control (HbA_1c_ <7 vs. ≥7 percent). We also considered the studies themselves as units for possible subgroup analysis—that is we performed between-study comparisons—for example when the mean age of participants fell within one of the age categories, or the majority (≥75 percent) of the participants were stated as racial/ethnic minorities (i.e., nonwhite but including Hispanic groups).

#### KQ 3 Potential Moderation of Effectiveness for T1DM—Components, Intensity, Delivery Personnel, Method of Communication, Degree of Tailoring, and Level of Community Engagement

To assess whether the effectiveness of behavioral programs differed based on various potential moderating factors, we performed univariate meta-regressions for comparisons between behavioral programs and usual care. We performed the analyses for HbA_1c_, which was the only outcome reported by at least 10 studies, and used data from each study's longest followup timepoint. There were insufficient studies to perform multivariable analysis. The following covariates were considered: program duration, program intensity (contact time), frequency of contacts (contacts per month), delivery mode, delivery personnel, presence of supports (e.g., family members), and community engagement. Each behavioral program was coded using the categorization scheme in Table 3.

#### KQ 4 Harms for T1DM

For harms (i.e., activity-related injury) we planned to descriptively summarize all outcomes presented in studies. We did not plan to conduct any quantitative analysis for this outcome.

### Synthesis for T2DM (KQs 5 and 6)

Before synthesizing findings to answer KQs 5 and 6, we performed pairwise meta-analyses for all outcomes identified in the PICOTS. This served to summarize the findings on outcomes not reported by enough studies to contribute to the analyses for KQ 5 or 6, and to provide information when interpreting the results of the subsequent analyses. We used the same analytical approach described for KQ 1.

#### KQ 5 Potential Moderation of Effectiveness for T2DM—Components, Intensity, Delivery Personnel, Method of Communication, and Level of Community Engagement

Rather than providing a simple pairwise comparison of similar comparisons (e.g., a group of interventions versus usual care) through standard meta-analysis, a network meta-analysis allows for simultaneous evaluation of a suite of comparisons while still preserving the within-study randomization. A network of different comparisons is constructed (with “nodes” representing groupings of sufficiently similar interventions and comparators) to consider both direct evidence from comparisons of similar interventions/nodes and indirect evidence from comparisons where one intervention is in common, but not all (e.g., intervention A vs. usual care, and intervention A vs. intervention B infer knowledge about intervention B vs. usual care). Because numerous nodes can be created, this approach can be useful when a diverse range of interventions and comparators are being considered—the nuances of the various interventions can be captured.

The grouping of behavioral programs into nodes was based on the categories in Table 3. We also formed three categories for the comparator groups: usual care, active “non-DSME” control (i.e., basic education not meeting our criteria for DSME; see Appendix A), and active “other” control (e.g., stand-alone dietary or physical activity intervention). For the intervention arms (behavioral programs), we identified all plausible nodes differing by only one variable (e.g., a level within the intensity category) to assess the variation in effectiveness based on the potential moderating factors of interest for this review. We then coded all interventions and comparators into the various nodes; not all plausible nodes ended up containing data. The analysis was conducted for HbA_1c_ and body mass index; because of the relatively low amount of outcome data for other key outcomes, only one or two variables could be considered and this was deemed to offer insufficient meaning.

The analysis was conducted using a Bayesian network model to compare all interventions simultaneously and to use all available information on treatment effects in a single analysis.79,80 These methods ensure that correlation in multi-armed trials is preserved. Mean differences were modeled using noninformative prior distributions. A normal prior distribution with mean 0 and large variance (10,000) was used for each of the trial means, whereas their between study variance had a uniform prior with range 0 to 2. These priors were checked for influence with sensitivity analyses. Markov Chain Monte Carlo simulations using WinBugs software were carried out to obtain simultaneous estimates of all interventions compared with placebo, as well as estimates of which interventions were the best. A burn-in sample of 20,000 iterations was followed by 300,000 iterations used to compute estimates. A sensitivity analysis that thinned the amount of used data to every tenth iteration was also conducted to check for proper chain convergence. The model formulation and WinBugs codes can be obtained at request of the authors. Analysis was checked for consistency by contrasting direct and indirect estimates in each triangular and quadratic loop using the methods described by Vernoiki.81 Results are presented as estimates of the treatment effects (MD) relative to usual care, 95 percent credibility intervals, as well as the rank probabilities for each behavioral program strategy (i.e., probability that a particular combination of components and delivery methods for a behavioral program is the “best program”).

#### KQ 6 Subgroups for Factors Moderating Effectiveness in T2DM

This KQ focused on whether variability between population groups affected the role of potential factors contributing to effectiveness of behavioral programs for the key outcome reported by the most studies (i.e., HbA_1c_). Similar to KQ 2, we searched for subgroup analyses reported by individual trials that focused on whether a particular behavioral program was more or less effective in reducing HbA_1c_ based on age (young adults [19-30 years], adults [31-64 years], older adults ≥65 years]), race or ethnicity, socioeconomic status, time since diagnosis (≤1 year vs. >1 year), and baseline level of glycemic control (HbA_1c_ <7 vs. ≥7 percent). This approach did not yield any appropriate data. We then considered the studies themselves as units for possible subgroup analysis.

As a starting point, we conducted subgroup analyses of the pairwise meta-analysis results for HbA_1c_ for behavioral programs compared with usual care and active controls at longest followup. When enough comparisons existed within an identified subgroup to maintain the structure of the network used for analysis of HbA_1c_ for KQ 5, we then performed subgroup analysis of this network. This was possible for studies with baseline HbA_1c_ ≥7 percent and with a mean participant age <65 years; the subgroups with baseline HbA_1c_ <7 percent and age ≥65 years were too small for their own network analysis. For subgroups based on race/ethnicity (≥75 vs. <75 percent minorities), the number of trials in either subgroup was insufficient, so we conducted a set of univariate meta-regressions within each subgroup using the variables in Table 3 and methods outlined for KQ 2. The number of studies did not allow for multivariable meta-regressions using the number of variables of interest.

## Strength of the Body of Evidence

We followed the Methods Guide59 to evaluate the strength of evidence (SOE) for KQ 1 for all health outcomes (i.e., quality of life, development of micro- and macrovascular complications, all-cause mortality) and selected behavioral and clinical outcomes (i.e., glycemic control, adherence to diabetes self-management behaviors, change in body composition, change in physical activity or fitness, and change in dietary or nutrient intake). For KQ 2, we assessed SOE for HbA_1c_ which was the outcome reported by the most studies and thus the focus of this KQ. SOE assessments were based on evidence from trials. The body of evidence was graded by one reviewer, and reviewed by a second reviewer. Disagreements were resolved through discussion or by consulting with a third reviewer, as needed.

We examined the five core domains most relevant to reviews of RCTs (anticipated to be the large majority of included studies): risk of bias, consistency, directness, precision, and reporting bias. We defined the risk of bias (low, medium, or high) on the basis of study design and methodological quality. We rated consistency (consistent, inconsistent, unknown [if there is only one study]) by assessing the direction and magnitude of the effects of the included studies. We assessed directness of the evidence (direct or indirect) on the basis of the use of surrogate outcomes or the need for indirect comparisons. We assessed precision (precise or imprecise) on the basis of the degree of certainty surrounding the effect estimate and based on sample size; for outcomes where clinically important thresholds were prespecified (i.e., HbA_1c_, HRQL, behavioral outcomes with continuous data), we downgraded the SOE twice for imprecision when the 95% CI crossed thresholds both for and against behavioral programs. A precise estimate is one that allows for a clinically useful conclusion. Reporting bias (suspected or unsuspected) was evaluated with respect to publication bias, selective outcome reporting bias, and selective analysis reporting bias. For selective reporting and analysis biases, we evaluated the results across studies qualitatively on the basis of completeness of reporting for individual studies and reporting patterns across studies. We rated the body of evidence using four SOE grades which indicate our level of confidence that the evidence reflects the true effect for the major comparisons of interest:

- High. Very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies; the findings are stable, i.e., another study would not change the conclusions.
- Moderate. We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies; the findings are likely to be stable, but some doubt remains.
- Low. We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both); additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient. We have no (or very little) evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome (i.e., the 95% CI of the effect estimate includes values representing clinically important magnitudes favoring both behavioral programs and the comparator).

We did not assess SOE for the KQs 3-6. KQ 4 assesses harms, which was a minor focus of this review. KQs 5 and 6 explore factors that may be associated with the effectiveness of behavioral programs; there is no precedent for SOE assessments for these types of questions.

## Applicability

We followed the Methods Guide to evaluate the applicability of the evidence to the delivery setting of interest (i.e., community health settings).59 We considered important population characteristics, behavioral program characteristics, and delivery settings that may limit applicability of the findings. Factors that may limit the applicability include narrow eligibility criteria, components or delivery elements of behavioral programs that may not be feasible in some settings, and health system differences.

## Peer Review and Public Commentary

Experts in behavioral medicine, diabetes education, clinical epidemiology, nutrition, physical education, psychology, and statistics fields, and individuals representing stakeholder and user communities were invited to provide external peer review of this report; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ website for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a disposition of comments report that will be made available 3 months after the Agency posts the final report on the AHRQ Effective Healthcare website.