# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Sharon A. Brown, Ph.D., R.N., FAAN
  Joseph H. Blades Centennial Memorial Professor in Nursing
  The University of Texas at Austin
  Austin, TX
- Rongwei (Rochelle) Fu, Ph.D.
  Associate Professor
  Department of Public Health and Preventative Medicine
  Oregon Health & Science University
  Portland, OR
- Steven T. Johnson, Ph.D.
  Assistant Professor
  Athabasca University
  Edmonton, AB, Canada
- Maya O'Neil, Ph.D.
  Assistant Professor of Psychology
  Departments of Psychiatry and Medical Informatics & Clinical Epidemiology
  Oregon Health & Science University
  Portland, OR