# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Ann Albright, Ph.D., R.D.
  Director, Division of Diabetes Translation
  National Center for Chronic Disease Prevention and Health Promotion
  Centers for Disease Control and Prevention
  Atlanta, GA
- Martha Funnell, M.S., R.N., C.D.E.^*^
  Associate Research Scientist
  Department of Learning Health Sciences
  University of Michigan Medical School
  Ann Arbor, MI
- Korey Hood, Ph.D.
  Clinical Professor, Pediatrics (Endocrinology and Diabetes), and Psychiatry and Behavioral Sciences
  Stanford University School of Medicine
  Stanford, CA
- Christine Hunter, Ph.D., A.B.B.P.^*^
  Director, Behavior Research
  National Institute of Diabetes and Digestive and Kidney Diseases
  Bethesda, MD
- Andrea Kriska, Ph.D.^*^
  Professor, Epidemiology
  Graduate School of Public Health
  University of Pittsburgh
  Pittsburgh, PA
- Carla Miller, Ph.D., R.D.^*^
  Professor, Human Nutrition
  Department of Human Sciences
  The Ohio State University
  Columbus, OH
- Shelagh Mulvaney, Ph.D.
  Assistant Professor, School of Nursing
  Assistant Director, Effective Health Communication Core
  Vanderbilt Institute for Clinical and Translational Research
  Vanderbilt University Medical Center
  Nashville, TN
- Gretchen Piatt, M.P.H., Ph.D.^*^
  Assistant Professor
  Department of Learning Health Sciences, School of Medicine
  Department of Health Behavior and Health Education, School of Public Health
  University of Michigan
  Ann Arbor, MI

* TEP members who provided comments on the draft report.