# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Christy Alberts
  Patient Representative
  Children's Diabetes Foundation
  Denver, CO
- Ann Albright, Ph.D., R.D.
  Director, Division of Diabetes Translation
  National Center for Chronic Disease Prevention and Health Promotion
  Centers for Disease Control and Prevention
  Atlanta, GA
- Jean Baltz, C.D.E., R.D., M.M.Sc., M.S.W.
  Diabetes Strategic Consultant
  Humana Inc.
  Louisville, KY
- Victoria DeFiglio, R.N.
  Associate Clinical Director
  Camden Coalition of Healthcare Providers
  Camden, NJ
- Philip Eager, M.Ed., N.C.C.
  Patient Representative
  Spokane, WA
- Korey Hood, Ph.D.
  Clinical Professor, Pediatrics (Endocrinology and Diabetes), and Psychiatry and Behavioral Sciences
  Stanford University School of Medicine
  Stanford, CA
- Christine Hunter, Ph.D., A.B.B.P.
  Director, Behavior Research
  National Institute of Diabetes and Digestive and Kidney Diseases
  Bethesda, MD
- Jeff Johnson, B.S.P., Ph.D.
  Professor
  School of Public Health
  University of Alberta
  Edmonton, AB, Canada
- Ann Lewis
  Chief Executive Officer
  CareSouth Carolina
  Hartsville, SC
- Molly McElwee, R.N., C.D.E., C.R.C.
  Clinical Research Coordinator
  Center for Diabetes Technology
  School of Medicine, University of Virginia
  Charlottesville, VA